# Regression Analyses for Citation Count and Journal Impact Factor

Appendix Table F1 Significant results from univariable regression analyses predicting the number of citations received by each paper per-year (all p-values were <0.001)

Factor | Relative Citation Rate (95% CI)
Clinical exam as test type | 0.64 (0.54, 0.76)
Graphical presentation of results | 1.39 (1.20, 1.61)
Number of studies | 1.01 (1.00, 1.01)
Pediatrics as topic | 0.52 (0.38, 0.72)
Use of advanced statistical methods | 1.48 (1.21, 1.79)
Orthopedics as topic | 0.62 (0.48, 0.81)
Reporting of comparative analyses between index tests | 1.32 (1.13, 1.54)

CI = confidence interval

Appendix Table F2 Significant results from univariable regression analyses predicting meta-analysis methods or reporting characteristics using journal impact factor as a predictor (all p-values were <0.001)

Methods or Reporting Characteristic | OR (95% CI) per Impact-Factor Unit
Clinical exam as test type | 1.06 (1.03, 1.08)
Use of likelihood ratios in quantitative analyses | 1.05 (1.03, 1.08)
Use of random effects models | 1.05 (1.03, 1.08)
Availability of the search strategy upon request | 1.07 (1.03, 1.11)
Assessment of blinding | 1.06 (1.02, 1.09)
Assessment of whether consecutive patients were enrolled | 1.04 (1.02, 1.07)
Use of review papers to identify eligible studies for meta-analysis | 1.04 (1.02, 1.07)

CI = confidence interval; OR = odds ratio

Appendix Table F3 Significant results from univariable regression analyses predicting meta-analysis methods or reporting characteristics using journal group as a predictor (high impact factor general medical journals versus all others; all p-values were <0.001)

Methods or Reporting Characteristic | OR (95% CI) (high-impact factor general medical journals versus all others)
Clinical exam as test type | 3.75 (2.03, 6.92)
Use of random effects models | 3.56 (1.78, 7.11)

CI = confidence interval; OR = odds ratio