# Regression Analyses for Trends Over Time

Appendix Table E1 Regression analyses for trends over time, for all studies included in the overview (publication years 1987 to 2009)

Characteristic | Per Year OR | P-Value
Cardiovascular disease | 0.99 (0.95, 1.03) | 0.585
Obstetrics and gynecology | 0.98 (0.94, 1.02) | 0.352
Gastrointestinal disease | 1.07 (1.02, 1.13) | 0.008
Infectious disease | 1.01 (0.97, 1.06) | 0.581
Oncology | 1.05 (1.01, 1.09) | 0.02
Nephrology and urology | 0.99 (0.92, 1.07) | 0.86
Rheumatology | 1.05 (0.88, 1.26) | 0.559
Pulmonary medicine | 1.10 (1.03, 1.18) | 0.005
Orthopedics | 1.09 (1.00, 1.19) | 0.041
Psychiatry | 1.12 (0.99, 1.27) | 0.077
Ear-nose-throat | 1.02 (0.92, 1.13) | 0.732
Neurology | 1.02 (0.95, 1.10) | 0.591
Pediatrics | 1.11 (1.00, 1.24) | 0.057
Histology | 0.99 (0.94, 1.03) | 0.58
Clinical exam | 1.00 (0.96, 1.05) | 0.857
Imaging | 1.00 (0.97, 1.03) | 0.905
Biomarker | 1.02 (0.98, 1.06) | 0.324
Clinical challenge tests | 1.11 (1.00, 1.23) | 0.046
Physiologic tests | 0.99 (0.92, 1.06) | 0.667
Endoscopy | 1.03 (0.93, 1.15) | 0.54
Exact search described | 1.09 (1.05, 1.14) | <0.001
Search terms provided | 1.01 (0.98, 1.05) | 0.424
Search on demand (on non-journal website or from the authors) | 1.03 (0.96, 1.11) | 0.367
Years searched were reported | 1.08 (1.02, 1.13) | 0.004
Quality criteria for study selection | 1.06 (1.02, 1.11) | 0.007
Consideration of English-language studies only | 0.96 (0.93, 1.00) | 0.028
Consideration of at least one language other than English | 1.05 (1.02, 1.09) | 0.003
Medline | 1.19 (1.11, 1.27) | <0.001
EMBASE | 1.28 (1.23, 1.35) | <0.001
Conference proceedings | 1.08 (1.02, 1.15) | 0.007
Reference lists of eligible studies | 1.02 (0.98, 1.06) | 0.315
Reference lists of relevant review articles | 1.01 (0.97, 1.04) | 0.672
SCI or other ISI databases | 1.18 (1.09, 1.28) | <0.001
Current Contents | 0.92 (0.86, 0.98) | 0.015
Experts in the field | 0.98 (0.94, 1.02) | 0.311
Test manufacturers | 1.05 (0.96, 1.15) | 0.259
Other specific electronic databases | 1.25 (1.18, 1.32) | <0.001
Hand searching of journals | 0.99 (0.95, 1.04) | 0.664
Cochrane databases | 1.30 (1.23, 1.38) | <0.001
CINAHL | 1.25 (1.15, 1.36) | <0.001
At least one electronic database in addition to Medline | 1.30 (1.24, 1.35) | <0.001
Unpublished information | 0.97 (0.93, 1.02) | 0.212
Any quality assessment | 1.34 (1.28, 1.40) | <0.001
Study settings | 1.03 (0.99, 1.06) | 0.114
Consecutive patient recruitment | 1.07 (1.04, 1.11) | <0.001
Prospective study design | 1.12 (1.09, 1.16) | <0.001
Details of the reference standard test | 0.98 (0.93, 1.03) | 0.487
Reader expertise | 1.12 (1.06, 1.19) | <0.001
Blinding (index test assessor to reference standard results) | 1.09 (0.98, 1.21) | 0.102
Blinding (reference standard test assessor to index test results) | 1.09 (0.98, 1.22) | 0.094
Blinding (unspecified) | 0.87 (0.75, 1.00) | 0.057
Any blinding | 1.09 (1.05, 1.13) | <0.001
Patient age | 1.15 (1.11, 1.20) | <0.001
Patient sex | 1.06 (0.95, 1.18) | 0.274
Location of primary studies | 1.20 (1.14, 1.27) | <0.001
Spectrum bias | 1.16 (1.04, 1.29) | 0.007
Selection bias | 1.14 (1.03, 1.27) | 0.015
Time between index and reference standard test application | 1.31 (1.17, 1.46) | <0.001
Test independence | 1.19 (1.07, 1.33) | 0.002
Indeterminate test results | 1.40 (1.24, 1.58) | <0.001
Withdrawals | 1.51 (1.33, 1.71) | <0.001
Verification bias | 1.17 (1.13, 1.22) | <0.001
QUADAS | 1.76 (1.57, 1.99) | <0.001
STARD | 1.32 (1.19, 1.47) | <0.001
Random effects used | 1.21 (1.16, 1.26) | <0.001
Bayesian analyses | 1.08 (0.95, 1.22) | 0.261
OR | 1.17 (1.12, 1.22) | <0.001
Sensitivity | 1.07 (1.03, 1.11) | <0.001
Specificity | 1.08 (1.04, 1.12) | <0.001
Likelihood ratios | 1.13 (1.08, 1.18) | <0.001
Accuracy | 0.97 (0.91, 1.04) | 0.359
Predictive values | 0.99 (0.95, 1.04) | 0.735
Q* | 0.91 (0.84, 0.97) | 0.007
AUC | 0.99 (0.92, 1.06) | 0.721
Any graphical display of analysis (synthesis) results | 1.13 (1.09, 1.17) | <0.001
Forest plots | 1.28 (1.22, 1.35) | <0.001
ROC space plots | 1.06 (1.03, 1.10) | <0.001
Heterogeneity testing | 1.21 (1.17, 1.26) | <0.001
Univariate analyses | 0.82 (0.76, 0.88) | <0.001
Comparative analyses | 0.98 (0.94, 1.02) | 0.292
Advanced synthesis methods | 1.27 (1.16, 1.39) | <0.001
Any exploration of heterogeneity | 1.08 (1.04, 1.12) | <0.001
Provides data for re-analyses | 0.96 (0.93, 1.00) | 0.027

Results are limited to 2004 onwards for the following variables: blinding (index test assessor to reference standard results, or reference standard assessor to index test results, or unspecified); selection bias; spectrum bias; extraction of data on participants' sex; withdrawals; indeterminate test results; timing; test independence. The STARD and QUADAS checklists were first published in January 2003 and November 2003, respectively.

AUC = area under the curve; CINAHL = Cumulative Index to Nursing and Allied Health Literature; OR = odds ratio; QUADAS = Quality Assessment of Diagnostic Accuracy Studies; ROC = receiver operating characteristic; STARD = Standards for Reporting of Diagnostic Accuracy.

Appendix Table E2 Regression analyses for trends over time, for studies included in the overview published since 2005 (publication years 2005 to 2009)

Characteristic | Per Year OR | P-value
Cardiovascular disease | 0.98 (0.83, 1.15) | 0.767
Obstetrics and gynecology | 1.18 (0.96, 1.44) | 0.117
Gastrointestinal disease | 0.92 (0.78, 1.09) | 0.331
Infectious disease | 0.87 (0.72, 1.05) | 0.141
Oncology | 1.05 (0.90, 1.23) | 0.498
Nephrology and urology | 0.78 (0.58, 1.06) | 0.113
Rheumatology | 1.25 (0.64, 2.46) | 0.514
Pulmonary medicine | 1.07 (0.86, 1.33) | 0.543
Orthopedics | 1.08 (0.82, 1.40) | 0.589
Psychiatry | 1.16 (0.79, 1.71) | 0.439
Ear-nose-throat | 0.87 (0.58, 1.30) | 0.488
Neurology | 1.15 (0.83, 1.61) | 0.398
Pediatrics | 1.01 (0.75, 1.37) | 0.929
Histology | 1.01 (0.83, 1.24) | 0.899
Clinical exam | 1.00 (0.83, 1.22) | 0.978
Imaging | 0.97 (0.85, 1.11) | 0.647
Biomarker | 1.01 (0.87, 1.17) | 0.905
Clinical challenge tests | 0.95 (0.69, 1.30) | 0.743
Physiologic tests | 0.81 (0.60, 1.11) | 0.200
Endoscopy | 1.31 (0.84, 2.05) | 0.237
Exact search described | 1.18 (1.02, 1.37) | 0.027
Search terms provided | 0.94 (0.82, 1.08) | 0.410
Search on demand (on non-journal website or from the authors) | 0.99 (0.73, 1.34) | 0.948
Years searched were reported | 1.13 (0.86, 1.49) | 0.372
Quality criteria for study selection | 1.13 (0.96, 1.34) | 0.151
Consideration of English-language studies only | 1.06 (0.92, 1.22) | 0.450
Consideration of at least one language other than English | 1.01 (0.88, 1.15) | 0.912
Medline | 1.52 (0.95, 2.44) | 0.079
EMBASE | 1.02 (0.89, 1.17) | 0.778
Conference proceedings | 1.13 (0.92, 1.38) | 0.242
Reference lists of eligible studies | 0.96 (0.82, 1.13) | 0.652
Reference lists of relevant review articles | 0.87 (0.75, 1.01) | 0.075
SCI or other ISI databases | 1.14 (0.94, 1.39) | 0.189
Current Contents | 1.16 (0.77, 1.75) | 0.480
Experts in the field | 0.84 (0.70, 1.02) | 0.073
Test manufacturers | 0.69 (0.49, 0.96) | 0.027
Other specific electronic databases | 1.14 (0.99, 1.31) | 0.065
Hand searching of journals | 0.74 (0.60, 0.91) | 0.004
Cochrane databases | 0.99 (0.86, 1.13) | 0.861
CINAHL | 0.98 (0.81, 1.18) | 0.818
At least one electronic database in addition to Medline | 1.20 (1.02, 1.41) | 0.031
Unpublished information | 0.84 (0.68, 1.05) | 0.123
Any quality assessment | 1.29 (1.03, 1.63) | 0.028
Study settings | 1.08 (0.94, 1.25) | 0.261
Consecutive patient recruitment | 0.89 (0.77, 1.02) | 0.084
Prospective study design | 0.84 (0.73, 0.98) | 0.025
Details of the reference standard test | 1.09 (0.89, 1.32) | 0.417
Reader expertise | 1.09 (0.92, 1.30) | 0.312
Blinding (index test assessor to reference standard results) | 1.12 (0.97, 1.28) | 0.113
Blinding (reference standard test assessor to index test results) | 1.12 (0.98, 1.28) | 0.106
Blinding (unspecified) | 0.78 (0.65, 0.95) | 0.011
Any blinding | 0.92 (0.79, 1.07) | 0.292
Patient age | 1.09 (0.95, 1.25) | 0.210
Patient sex | 1.09 (0.95, 1.25) | 0.224
Location of primary studies | 1.07 (0.92, 1.23) | 0.385
Spectrum bias | 1.16 (1.02, 1.33) | 0.029
Selection bias | 1.11 (0.96, 1.27) | 0.148
Time between index and reference standard test application | 1.33 (1.16, 1.54) | <0.001
Test independence | 1.10 (0.96, 1.26) | 0.189
Indeterminate test results | 1.29 (1.12, 1.49) | 0.001
Withdrawals | 1.42 (1.22, 1.65) | <0.001
Verification bias | 0.97 (0.84, 1.11) | 0.625
QUADAS | 1.46 (1.25, 1.71) | <0.001
STARD | 1.03 (0.84, 1.25) | 0.789
Random effects used | 1.13 (0.97, 1.31) | 0.113
Bayesian analyses | 1.12 (0.70, 1.78) | 0.634
OR | 1.21 (1.05, 1.39) | 0.007
Sensitivity | 1.14 (0.96, 1.35) | 0.144
Specificity | 1.18 (1.00, 1.39) | 0.046
Likelihood ratios | 1.09 (0.95, 1.26) | 0.221
Accuracy | 0.93 (0.67, 1.28) | 0.640
Predictive values | 1.05 (0.86, 1.28) | 0.639
Q* | 0.99 (0.55, 1.76) | 0.964
AUC | 1.39 (0.93, 2.06) | 0.109
Any graphical display of analysis (synthesis) results | 1.13 (0.94, 1.35) | 0.190
Forest plots | 1.26 (1.09, 1.44) | 0.001
ROC space plots | 0.99 (0.87, 1.14) | 0.920
Heterogeneity testing | 1.03 (0.88, 1.20) | 0.743
Univariate analyses | 0.95 (0.79, 1.13) | 0.543
Comparative analyses | 0.84 (0.70, 1.00) | 0.056
Advanced synthesis methods | 1.39 (1.13, 1.71) | 0.002
Any exploration of heterogeneity | 0.99 (0.86, 1.14) | 0.862
Provides data for re-analyses | 0.95 (0.83, 1.09) | 0.458

Results are presented for 2005 onwards for all variables.

AUC = area under the curve; CINAHL = Cumulative Index to Nursing and Allied Health Literature; OR = odds ratio; QUADAS = Quality Assessment of Diagnostic Accuracy Studies; ROC = receiver operating characteristic; STARD = Standards for Reporting of Diagnostic Accuracy.

Appendix Table E3 Regression analyses comparing meta-analyses before and after the introduction of QUADAS and STARD (2003 or later versus 2002 or earlier)

Characteristic | Per Year OR | P-value
Cardiovascular disease | 0.95 (0.65, 1.40) | 0.805
Obstetrics and gynecology | 0.84 (0.54, 1.28) | 0.409
Gastrointestinal disease | 2.62 (1.54, 4.44) | <0.001
Infectious disease | 1.40 (0.85, 2.30) | 0.182
Oncology | 1.54 (1.05, 2.25) | 0.028
Nephrology and urology | 1.16 (0.56, 2.44) | 0.687
Rheumatology | 1.24 (0.25, 6.19) | 0.793
Pulmonary medicine | 2.27 (1.17, 4.42) | 0.016
Orthopedics | 2.27 (1.00, 5.17) | 0.051
Psychiatry | 2.67 (0.78, 9.12) | 0.117
Ear-nose-throat | 0.89 (0.33, 2.38) | 0.818
Neurology | 1.52 (0.69, 3.39) | 0.301
Pediatrics | 2.66 (0.91, 7.72) | 0.073
Histology | 1.06 (0.67, 1.68) | 0.800
Clinical exam | 1.04 (0.67, 1.62) | 0.872
Imaging | 0.98 (0.71, 1.34) | 0.891
Biomarker | 1.37 (0.96, 1.97) | 0.087
Clinical challenge tests | 2.88 (1.00, 8.33) | 0.051
Physiologic tests | 0.75 (0.39, 1.47) | 0.409
Endoscopy | 1.03 (0.40, 2.70) | 0.948
Exact search described | 1.70 (1.16, 2.50) | 0.007
Search terms provided | 1.17 (0.85, 1.60) | 0.333
Search on demand (on non-journal website or from the authors) | 1.39 (0.67, 2.86) | 0.379
Years searched were reported | 1.93 (1.14, 3.27) | 0.014
Quality criteria for study selection | 1.52 (1.00, 2.33) | 0.052
Consideration of English-language studies only | 0.63 (0.46, 0.87) | 0.005
Consideration of at least one language other than English | 1.70 (1.23, 2.36) | 0.001
Medline | 4.74 (2.23, 10.08) | <0.001
EMBASE | 9.13 (6.04, 13.79) | <0.001
Conference proceedings | 1.57 (0.92, 2.68) | 0.097
Reference lists of eligible studies | 1.20 (0.84, 1.71) | 0.328
Reference lists of relevant review articles | 1.22 (0.86, 1.74) | 0.270
SCI or other ISI databases | 5.21 (2.23, 12.19) | <0.001
Current Contents | 0.37 (0.19, 0.73) | 0.004
Experts in the field | 0.79 (0.53, 1.18) | 0.253
Test manufacturers | 1.90 (0.77, 4.67) | 0.161
Other specific electronic databases | 6.80 (3.97, 11.66) | <0.001
Hand searching of journals | 0.93 (0.60, 1.46) | 0.759
Cochrane databases | 16.25 (8.16, 32.35) | <0.001
CINAHL | 12.56 (3.92, 40.24) | <0.001
At least one electronic database in addition to Medline | 8.76 (6.13, 12.52) | <0.001
Unpublished information | 0.72 (0.46, 1.14) | 0.157
Any quality assessment | 11.27 (7.81, 16.27) | <0.001
Study settings | 1.21 (0.88, 1.68) | 0.241
Consecutive patient recruitment | 1.97 (1.41, 2.74) | <0.001
Prospective study design | 3.11 (2.25, 4.30) | <0.001
Details of the reference standard test | 0.68 (0.40, 1.13) | 0.135
Reader expertise | 2.72 (1.58, 4.67) | <0.001
Blinding (index test assessor to reference standard results) | NA | NA
Blinding (reference standard test assessor to index test results) | NA | NA
Blinding (unspecified) | NA | NA
Any blinding | 2.32 (1.68, 3.20) | <0.001
Patient age | 3.88 (2.74, 5.49) | <0.001
Patient sex | NA | NA
Location of primary studies | 7.22 (4.08, 12.78) | <0.001
Spectrum bias | NA | NA
Selection bias | NA | NA
Time between index and reference standard test application | NA | NA
Test independence | NA | NA
Indeterminate test results | NA | NA
Withdrawals | NA | NA
Verification bias | 4.33 (3.05, 6.15) | <0.001
QUADAS | NA | NA
STARD | NA | NA
Random effects used | 5.21 (3.70, 7.32) | <0.001
Bayesian analyses | 3.15 (0.72, 13.91) | 0.129
OR | 3.32 (2.25, 4.91) | <0.001
Sensitivity | 1.77 (1.25, 2.53) | 0.001
Specificity | 2.02 (1.44, 2.84) | <0.001
Likelihood ratios | 2.82 (1.91, 4.17) | <0.001
Accuracy | 0.65 (0.34, 1.24) | 0.196
Predictive values | 0.91 (0.57, 1.45) | 0.691
Q* | 0.24 (0.11, 0.55) | 0.001
AUC | 0.60 (0.31, 1.15) | 0.127
Any graphical display of analysis (synthesis) results | 2.92 (2.08, 4.11) | <0.001
Forest plots | 7.44 (4.81, 11.51) | <0.001
ROC space plots | 1.66 (1.21, 2.27) | 0.002
Heterogeneity testing | 5.34 (3.80, 7.52) | <0.001
Univariate analyses | 0.06 (0.02, 0.20) | <0.001
Comparative analyses | 0.79 (0.53, 1.18) | 0.253
Advanced synthesis methods | 9.10 (3.29, 25.19) | <0.001
Any exploration of heterogeneity | 1.89 (1.38, 2.59) | <0.001
Provides data for re-analyses | 0.74 (0.54, 1.03) | 0.071

AUC = area under the curve; CINAHL = Cumulative Index to Nursing and Allied Health Literature; NA = not available (indicates that estimation was not possible due to unavailability of data for a variable or perfect prediction); OR = odds ratio; QUADAS = Quality Assessment of Diagnostic Accuracy Studies; ROC = receiver operating characteristic; STARD = Standards for Reporting of Diagnostic Accuracy.