# Reasons for Exclusion

Reasons for Exclusion | Studies
Not meta-analyses of test accuracy | 319
Cochrane Reviews/ Health Technology Assessments | 32
Individual Patient Data meta-analyses | 14
Narrative reviews | 54
Editorials/ letters/ commentaries | 17
Methodological contributions | 13
Risk score meta-analyses | 4
Meta-analyses of continuous outcomes | 4
No gold standard | 4
Duplicate publications | 3
Animal study | 1
TOTAL | 465