# List of Included Studies

1 Abbas SM, Bissett IP, Parry BR. Meta-analysis of oral water-soluble contrast agent in the management of adhesive small bowel obstruction. Br J Surg. 2007;94(4):404-11. [pmid: 17380561].
2 Abdelmoneim SS, Dhoble A, Bernier M, et al. Quantitative myocardial contrast echocardiography during pharmacological stress for diagnosis of coronary artery disease: a systematic review and meta-analysis of diagnostic accuracy studies. Eur J Echocardiogr. 2009;10(7):813-25. [pmid: 19549700].
3 Abdulla J, Abildstrom SZ, Gotzsche O, et al. 64-multislice detector computed tomography coronary angiography as potential alternative to conventional coronary angiography: a systematic review and meta-analysis. Eur Heart J. 2007;28(24):3042-50. [pmid: 17981829].
4 Abdulla J, Sivertsen J, Kofoed KF, et al. Evaluation of aortic valve stenosis by cardiac multislice computed tomography compared with echocardiography: a systematic review and meta-analysis. J Heart Valve Dis. 2009;18(6):634-43. [pmid: 20099712].
5 Abulafia O, Sherer DM. Automated cervical cytology: meta-analyses of the performance of the AutoPap 300 QC System. Obstet Gynecol Surv. 1999;54(7):469-76. [pmid: 10394585].
6 Adams K, Shah PL, Edmonds L, et al. Test performance of endobronchial ultrasound and transbronchial needle aspiration biopsy for mediastinal staging in patients with lung cancer: systematic review and meta-analysis. Thorax. 2009;64(9):757-62. [pmid: 19454408].
7 Aertgeerts B, Buntinx F, Kester A. The value of the CAGE in screening for alcohol abuse and alcohol dependence in general clinical populations: a diagnostic meta-analysis. J Clin Epidemiol. 2004;57(1):30-9. [pmid: 15019008].
8 Ahmad S, Beckett MW. Value of serum prolactin in the management of syncope. Emerg Med J. 2004;21(2):e3. [pmid: 14988379].
9 Akcil M, Karaagaoglu E, Demirhan B. Diagnostic accuracy of fine-needle aspiration cytology of palpable breast masses: an SROC curve with fixed and random effects linear meta-regression models. Diagn Cytopathol. 2008;36(5):303-10. [pmid: 18418880].
10 Alongi F, Ragusa P, Montemaggi P, et al. Combining independent studies of diagnostic fluorodeoxyglucose positron-emission tomography and computed tomography in mediastinal lymph node staging for non-small cell lung cancer. Tumori. 2006;92(4):327-33. [pmid: 17036525].
11 Alvarez Amezaga J, Barbier Herrero L, Pijoan del Barrio JI, et al. Diagnostic efficacy of sentinel node biopsy in oral squamous cell carcinoma. Cohort study and meta-analysis. Med Oral Patol Oral Cir Bucal. 2007;12(3):E235-43. [pmid: 17468723].
12 Alvarez S, Anorbe E, Alcorta P, et al. Role of sonography in the diagnosis of axillary lymph node metastases in breast cancer: a systematic review. AJR Am J Roentgenol. 2006;186(5):1342-8. [pmid: 16632729].
13 Anderson BA, Salem L, Flum DR. A systematic review of whether oral contrast is necessary for the computed tomography diagnosis of appendicitis in adults. Am J Surg. 2005;190(3):474-8. [pmid: 16105539].
14 Andersson RE. Meta-analysis of the clinical and laboratory diagnosis of appendicitis. Br J Surg. 2004;91(1):28-37. [pmid: 14716790].
15 Annovazzi A, Bagni B, Burroni L, et al. Nuclear medicine imaging of inflammatory/infective disorders of the abdomen. Nucl Med Commun. 2005;26(7):657-64. [pmid: 15942487].
16 Arbyn M, Buntinx F, Van Ranst M, et al. Virologic versus cytologic triage of women with equivocal Pap smears: a meta-analysis of the accuracy to detect high-grade intraepithelial neoplasia. J Natl Cancer Inst. 2004;96(4):280-93. [pmid: 14970277].
17 Arbyn M, Martin-Hirsch P, Buntinx F, et al. Triage of women with equivocal or low-grade cervical cytology results: a meta-analysis of the HPV test positivity rate. J Cell Mol Med. 2009;13(4):648-59. [pmid: 19166485].
18 Arbyn M, Paraskevaidis E, Martin-Hirsch P, et al. Clinical utility of HPV-DNA detection: triage of minor cervical lesions, follow-up of women treated for high-grade CIN: an update of pooled evidence. Gynecol Oncol. 2005;99(3 Suppl 1):S7-11. [pmid: 16154623].
19 Arbyn M, Schenck U. Detection of false negative Pap smears by rapid reviewing. A metaanalysis. Acta Cytol. 2000;44(6):949-57. [pmid: 11127751].
20 Arbyn M, Schenck U, Ellison E, et al. Metaanalysis of the accuracy of rapid prescreening relative to full screening of pap smears. Cancer. 2003;99(1):9-16. [pmid: 12589640].
21 Ashoke R, Brown LC, Rodway A, et al. Color duplex ultrasonography is insensitive for the detection of endoleak after aortic endografting: a systematic review. J Endovasc Ther. 2005;12(3):297-305. [pmid: 15943504].
22 Atieh MA. Accuracy of real-time polymerase chain reaction versus anaerobic culture in detection of Aggregatibacter actinomycetemcomitans and Porphyromonas gingivalis: a meta-analysis. J Periodontol. 2008;79(9):1620-9. [pmid: 18771361].
23 Attia J, Hatala R, Cook DJ, et al. The rational clinical examination. Does this adult patient have acute meningitis?. JAMA. 1999;282(2):175-81. [pmid: 10411200].
24 Bachmann LM, Haberzeth S, Steurer J, et al. The accuracy of the Ottawa knee rule to rule out knee fractures: a systematic review. Ann Intern Med. 2004;140(2):121-4. [pmid: 14734335].
25 Bachmann LM, Kolb E, Koller MT, et al. Accuracy of Ottawa ankle rules to exclude fractures of the ankle and mid-foot: systematic review. BMJ. 2003;326(7386):417. [pmid: 12595378].
26 Bachmann MO, Nelson SJ. Impact of diabetic retinopathy screening on a British district population: case detection and blindness prevention in an evidence-based model. J Epidemiol Community Health. 1998;52(1):45-52. [pmid: 9604041].
27 Badgett RG, Lucey CR, Mulrow CD. Can the clinical examination diagnose left-sided heart failure in adults?. JAMA. 1997;277(21):1712-9. [pmid: 9169900].
28 Badgett RG, Mulrow CD, Otto PM, et al. How well can the chest radiograph diagnose left ventricular dysfunction?. J Gen Intern Med. 1996;11(10):625-34. [pmid: 8945695].
29 Bafounta ML, Beauchet A, Aegerter P, et al. Is dermoscopy (epiluminescence microscopy) useful for the diagnosis of melanoma? Results of a meta-analysis using techniques adapted to the evaluation of diagnostic tests. Arch Dermatol. 2001;137(10):1343-50. [pmid: 11594860].
30 Bafounta ML, Beauchet A, Chagnon S, et al. Ultrasonography or palpation for detection of melanoma nodal invasion: a meta-analysis. Lancet Oncol. 2004;5(11):673-80. [pmid: 15522655].
31 Bagai A, Thavendiranathan P, Detsky AS. Does this patient have hearing impairment?. JAMA. 2006;295(4):416-28. [pmid: 16434632].
32 Bailey B, Buckley NA, Amre DK. A meta-analysis of prognostic indicators to predict seizures, arrhythmias or death after tricyclic antidepressant overdose. J Toxicol Clin Toxicol. 2004;42(6):877-88. [pmid: 15533027].
33 Bailey JJ, Berson AS, Handelsman H, et al. Utility of current risk stratification tests for predicting major arrhythmic events after myocardial infarction. J Am Coll Cardiol. 2001;38(7):1902-11. [pmid: 11738292].
34 Baker PA, Depuydt A, Thompson JM. Thyromental distance measurement—fingers don't rule. Anaesthesia. 2009;64(8):878-82. [pmid: 19604192].
35 Bakis S, Irwig L, Wood G, et al. Exfoliative cytology as a diagnostic test for basal cell carcinoma: a meta-analysis. Br J Dermatol. 2004;150(5):829-36. [pmid: 15149493].
36 Balk EM, Ioannidis JP, Salem D, et al. Accuracy of biomarkers to diagnose acute cardiac ischemia in the emergency department: a meta-analysis. Ann Emerg Med. 2001;37(5):478-94. [pmid: 11326184].
37 Banal F, Dougados M, Combescure C, et al. Sensitivity and specificity of the American College of Rheumatology 1987 criteria for the diagnosis of rheumatoid arthritis according to disease duration: a systematic literature review and meta-analysis. Ann Rheum Dis. 2009;68(7):1184-91. [pmid: 18728049].
38 Barnes CJ, Pietrobon R, Higgins LD. Does the pulse examination in patients with traumatic knee dislocation predict a surgical arterial injury? A meta-analysis. J Trauma. 2002;53(6):1109-14. [pmid: 12478036].
39 Basaran A, Basaran M. Diagnosis of acute appendicitis during pregnancy: a systematic review. Obstet Gynecol Surv. 2009;64(7):481-8. quiz 99. [pmid: 19545456].
40 Bastiaannet E, Groen H, Jager PL, et al. The value of FDG-PET in the detection, grading and response to therapy of soft tissue and bone sarcomas; a systematic review and meta-analysis. Cancer Treat Rev. 2004;30(1):83-101. [pmid: 14766127].
41 Bastian LA, Nanda K, Hasselblad V, et al. Diagnostic efficiency of home pregnancy test kits. A meta-analysis. Arch Fam Med. 1998;7(5):465-9. [pmid: 9755740].
42 Battaglia M, Pewsner D, Juni P, et al. Accuracy of B-type natriuretic peptide tests to exclude congestive heart failure: systematic review of test accuracy studies. Arch Intern Med. 2006;166(10):1073-80. [pmid: 16717169].
43 Bax JJ, Poldermans D, Elhendy A, et al. Sensitivity, specificity, and predictive accuracies of various noninvasive techniques for detecting hibernating myocardium. Curr Probl Cardiol. 2001;26(2):147-86. [pmid: 11276916].
44 Bax JJ, Wijns W, Cornel JH, et al. Accuracy of currently available techniques for prediction of functional recovery after revascularization in patients with left ventricular dysfunction due to chronic coronary artery disease: comparison of pooled data. J Am Coll Cardiol. 1997;30(6):1451-60. [pmid: 9362401].
45 Beach J, Russell K, Blitz S, et al. A systematic review of the diagnosis of occupational asthma. Chest. 2007;131(2):569-78. [pmid: 17296663].
46 Beattie WS, Abdelnaem E, Wijeysundera DN, et al. A meta-analytic comparison of preoperative stress echocardiography and nuclear scintigraphy imaging. Anesth Analg. 2006;102(1):8-16. [pmid: 16368798].
47 Benatar M. A systematic review of diagnostic studies in myasthenia gravis. Neuromuscul Disord. 2006;16(7):459-67. [pmid: 16793269].
48 Benjaminse A, Gokeler A, van der Schans CP. Clinical diagnosis of an anterior cruciate ligament rupture: a meta-analysis. J Orthop Sports Phys Ther. 2006;36(5):267-88. [pmid: 16715828].
49 Benninger MS, Payne SC, Ferguson BJ, et al. Endoscopically directed middle meatal cultures versus maxillary sinus taps in acute bacterial maxillary rhinosinusitis: a meta-analysis. Otolaryngol Head Neck Surg. 2006;134(1):3-9. [pmid: 16399172].
50 Berger MY, van der Velden JJ, Lijmer JG, et al. Abdominal symptoms: do they predict gallstones? A systematic review. Scand J Gastroenterol. 2000;35(1):70-6. [pmid: 10672838].
51 Berman DS, Kiat H, Van Train KF, et al. Comparison of SPECT using technetium-99m agents and thallium-201 and PET for the assessment of myocardial perfusion and viability. Am J Cardiol. 1990;66(13):72E-9E.
52 Berner MM, Kriston L, Bentele M, et al. The alcohol use disorders identification test for detecting at-risk drinking: a systematic review and meta-analysis. J Stud Alcohol Drugs. 2007;68(3):461-73. [pmid: 17446987].
53 Bhardwaj A, Hollenbeak CS, Pooran N, et al. A meta-analysis of the diagnostic accuracy of esophageal capsule endoscopy for Barrett's esophagus in patients with gastroesophageal reflux disease. Am J Gastroenterol. 2009;104(6):1533-9. [pmid: 19491867].
54 Bipat S, Glas AS, Slors FJ, et al. Rectal cancer: local staging and assessment of lymph node involvement with endoluminal US, CT, and MR imaging—a meta-analysis. Radiology. 2004;232(3):773-83. [pmid: 15273331].
55 Bipat S, Glas AS, van der Velden J, et al. Computed tomography and magnetic resonance imaging in staging of uterine cervical carcinoma: a systematic review. Gynecol Oncol. 2003;91(1):59-66. [pmid: 14529663].
56 Bipat S, Phoa SS, van Delden OM, et al. Ultrasonography, computed tomography and magnetic resonance imaging for diagnosis and determining resectability of pancreatic adenocarcinoma: a meta-analysis. J Comput Assist Tomogr. 2005;29(4):438-45. [pmid: 16012297].
57 Bipat S, van Leeuwen MS, Comans EF, et al. Colorectal liver metastases: CT, MR imaging, and PET for diagnosis—meta-analysis. Radiology. 2005;237(1):123-31. [pmid: 16100087].
58 Birim O, Kappetein AP, Stijnen T, et al. Meta-analysis of positron emission tomographic and computed tomographic imaging in detecting mediastinal lymph node metastases in nonsmall cell lung cancer. Ann Thorac Surg. 2005;79(1):375-82. [pmid: 15620991].
59 Blacksell SD, Doust JA, Newton PN, et al. A systematic review and meta-analysis of the diagnostic accuracy of rapid immunochromatographic assays for the detection of dengue virus IgM antibodies during acute infection. Trans R Soc Trop Med Hyg. 2006;100(8):775-84. [pmid: 16551470].
60 Blakeley DD, Oddone EZ, Hasselblad V, et al. Noninvasive carotid artery testing. A meta-analytic review. Ann Intern Med. 1995;122(5):360-7. [pmid: 7847648].
61 Blaufox MD, Middleton ML, Bongiovanni J, et al. Cost efficacy of the diagnosis and therapy of renovascular hypertension. J Nucl Med. 1996;37(1):171-7. [pmid: 8543990].
62 Bonis PA, Ioannidis JP, Cappelleri JC, et al. Correlation of biochemical response to interferon alfa with histological improvement in hepatitis C: a meta-analysis of diagnostic test characteristics. Hepatology. 1997;26(4):1035-44. [pmid: 9328332].
63 Booth CM, Boone RH, Tomlinson G, et al. Is this patient dead, vegetative, or severely neurologically impaired? Assessing outcome for comatose survivors of cardiac arrest. JAMA. 2004;291(7):870-9. [pmid: 14970067].
64 Brealey S, Scally A, Hahn S, et al. Accuracy of radiographer plain radiograph reporting in clinical practice: a meta-analysis. Clin Radiol. 2005;60(2):232-41. [pmid: 15664578].
65 Brealey S, Scally A, Hahn S, et al. Accuracy of radiographers red dot or triage of accident and emergency radiographs in clinical practice: a systematic review. Clin Radiol. 2006;61(7):604-15. [pmid: 16784947].
66 Brennan ME, Houssami N, Lord S, et al. Magnetic resonance imaging screening of the contralateral breast in women with newly diagnosed breast cancer: systematic review and meta-analysis of incremental cancer detection and impact on surgical management. J Clin Oncol. 2009;27(33):5640-9. [pmid: 19805685].
67 Brietzke SE, Katz ES, Roberson DW. Can history and physical examination reliably diagnose pediatric obstructive sleep apnea/hypopnea syndrome? A systematic review of the literature. Otolaryngol Head Neck Surg. 2004;131(6):827-32. [pmid: 15577775].
68 Broekmans FJ, Kwee J, Hendriks DJ, et al. A systematic review of tests predicting ovarian reserve and IVF outcome. Hum Reprod Update. 2006;12(6):685-718. [pmid: 16891297].
69 Broer SL, Mol BW, Hendriks D, et al. The role of antimullerian hormone in prediction of outcome after IVF: comparison with the antral follicle count. Fertil Steril. 2009;91(3):705-14. [pmid: 18321493].
70 Brouwer J, Hooft L, Hoekstra OS, et al. Systematic review: accuracy of imaging tests in the diagnosis of recurrent laryngeal carcinoma after radiotherapy. Head Neck. 2008;30(7):889-97. [pmid: 18213716].
71 Brown DL, Doubilet PM. Transvaginal sonography for diagnosing ectopic pregnancy: positivity criteria and performance characteristics. J Ultrasound Med. 1994;13(4):259-66. [pmid: 7932989].
72 Brown MD, Lau J, Nelson RD, et al. Turbidimetric D-dimer test in the diagnosis of pulmonary embolism: a metaanalysis. Clin Chem. 2003;49(11):1846-53. [pmid: 14578316].
73 Brown MD, Rowe BH, Reeves MJ, et al. The accuracy of the enzyme-linked immunosorbent assay D-dimer test in the diagnosis of pulmonary embolism: a meta-analysis. Ann Emerg Med. 2002;40(2):133-44. [pmid: 12140491].
74 Bruyninckx R, Aertgeerts B, Bruyninckx P, et al. Signs and symptoms in diagnosing acute myocardial infarction and acute coronary syndrome: a diagnostic meta-analysis. Br J Gen Pract. 2008;58(547):105-11. [pmid: 18307844].
75 Buntinx F, Wauters H. The diagnostic value of macroscopic haematuria in diagnosing urological cancers: a meta-analysis. Fam Pract. 1997;14(1):63-8. [pmid: 9061347].
76 Burnside PR, Brown MD, Kline JA. Systematic review of emergency physician-performed ultrasonography for lower-extremity deep vein thrombosis. Acad Emerg Med. 2008;15(6):493-8. [pmid: 18616433].
77 Bwanga F, Hoffner S, Haile M, et al. Direct susceptibility testing for multi drug resistant tuberculosis: a meta-analysis. BMC Infect Dis. 2009;9:67. [pmid: 19457256].
78 Cabana MD, Alavi A, Berlin JA, et al. Morphine-augmented hepatobiliary scintigraphy: a meta-analysis. Nucl Med Commun. 1995;16(12):1068-71. [pmid: 8719990].
79 Campens D, Buntinx F. Selecting the best renal function tests. A meta-analysis of diagnostic studies. Int J Technol Assess Health Care. 1997;13(2):343-56. [pmid: 9194355].
80 Carlson KJ, Skates SJ, Singer DE. Screening for ovarian cancer. Ann Intern Med. 1994;121(2):124-32. [pmid: 8017726].
81 Carroll T, Raff H, Findling JW. Late-night salivary cortisol for the diagnosis of Cushing syndrome: a meta-analysis. Endocr Pract. 2009;15(4):335-42. [pmid: 19502211].
82 Carter BG, Butt W. Review of the use of somatosensory evoked potentials in the prediction of outcome after severe brain injury. Crit Care Med. 2001;29(1):178-86. [pmid: 11176182].
83 Carter BG, Butt W. Are somatosensory evoked potentials the best predictor of outcome after severe brain injury? A systematic review. Intensive Care Med. 2005;31(6):765-75. [pmid: 15846481].
84 Cascini GL, De Palma D, Matteucci F, et al. Fever of unknown origin, infection of subcutaneous devices, brain abscesses and endocarditis. Nucl Med Commun. 2006;27(3):213-22. [pmid: 16479240].
85 Castilla-Rilo J, Lopez-Arrieta J, Bermejo-Pareja F, et al. Instrumental activities of daily living in the screening of dementia in population studies: a systematic review and meta-analysis. Int J Geriatr Psychiatry. 2007;22(9):829-36. [pmid: 17236250].
86 Cavallazzi R, Nair A, Vasu T, et al. Natriuretic peptides in acute pulmonary embolism: a systematic review. Intensive Care Med. 2008;34(12):2147-56. [pmid: 18626627].
87 Cepoiu M, McCusker J, Cole MG, et al. Recognition of depression by non-psychiatric physicians—a systematic literature review and meta-analysis. J Gen Intern Med. 2008;23(1):25-36. [pmid: 17968628].
88 Chalco JP, Huicho L, Alamo C, et al. Accuracy of clinical pallor in the diagnosis of anaemia in children: a meta-analysis. BMC Pediatr. 2005;5:46. [pmid: 16336667].
89 Chan BK, Melnikow J, Slee CA, et al. Posttreatment human papillomavirus testing for recurrent cervical intraepithelial neoplasia: a systematic review. Am J Obstet Gynecol. 2009;200(4):e1-9.
90 Chaparro M, Gisbert JP, Del Campo L, et al. Accuracy of computed tomographic colonography for the detection of polyps and colorectal tumors: a systematic review and meta-analysis. Digestion. 2009;80(1):1-17. [pmid: 19407448].
91 Chappell ET, Moure FC, Good MC. Comparison of computed tomographic angiography with digital subtraction angiography in the diagnosis of cerebral aneurysms: a meta-analysis. Neurosurgery. 2003;52(3):624-31. discussion 30-1. [pmid: 12590688].
92 Chappuis F, Rijal S, Soto A, et al. A meta-analysis of the diagnostic performance of the direct agglutination test and rK39 dipstick for visceral leishmaniasis. BMJ. 2006;333(7571):723. [pmid: 16882683].
93 Chen SC, Bravata DM, Weil E, et al. A comparison of dermatologists' and primary care physicians' accuracy in diagnosing melanoma: a systematic review. Arch Dermatol. 2001;137(12):1627-34. [pmid: 11735713].
94 Cher DJ, Conwell JA, Mandel JS. MRI for detecting silicone breast implant rupture: meta-analysis and implications. Ann Plast Surg. 2001;47(4):367-80. [pmid: 11601570].
95 Chien PF, Arnott N, Gordon A, et al. How useful is uterine artery Doppler flow velocimetry in the prediction of pre-eclampsia, intrauterine growth retardation and perinatal death? An overview. BJOG. 2000;107(2):196-208. [pmid: 10688503].
96 Chien PF, Khan KS, Ogston S, et al. The diagnostic accuracy of cervico-vaginal fetal fibronectin in predicting preterm delivery: an overview. Br J Obstet Gynaecol. 1997;104(4):436-44. [pmid: 9141580].
97 Chin AS, Goldman LE, Eisenberg MJ. Functional testing after coronary artery bypass graft surgery: a meta-analysis. Can J Cardiol. 2003;19(7):802-8. [pmid: 12813614].
98 Choi HK, Liu S, Merkel PA, et al. Diagnostic performance of antineutrophil cytoplasmic antibody tests for idiopathic vasculitides: metaanalysis with a focus on antimyeloperoxidase antibodies. J Rheumatol. 2001;28(7):1584-90. [pmid: 11469466].
99 Christou MA, Siontis GC, Katritsis DG, et al. Meta-analysis of fractional flow reserve versus quantitative coronary angiography and noninvasive imaging for evaluation of myocardial ischemia. Am J Cardiol. 2007;99(4):450-6. [pmid: 17293182].
100 Chua AE, Ridley LJ. Diagnostic accuracy of CT angiography in acute gastrointestinal bleeding. J Med Imaging Radiat Oncol. 2008;52(4):333-8. [pmid: 18811756].
101 Chun AA, McGee SR. Bedside diagnosis of coronary artery disease: a systematic review. Am J Med. 2004;117(5):334-43. [pmid: 15336583].
102 Cinnella G, Dambrosio M, Brienza N, et al. Transesophageal echocardiography for diagnosis of traumatic aortic injury: an appraisal of the evidence. J Trauma. 2004;57(6):1246-55. [pmid: 15625457].
103 Clark TJ, Mann CH, Shah N, et al. Accuracy of outpatient endometrial biopsy in the diagnosis of endometrial hyperplasia. Acta Obstet Gynecol Scand. 2001;80(9):784-93. [pmid: 11531627].
104 Clark TJ, ter Riet G, Coomarasamy A, et al. Bias associated with delayed verification in test accuracy studies: accuracy of tests for endometrial hyperplasia may be much higher than we think!. BMC Med. 2004;2:18. [pmid: 15137911].
105 Clark TJ, Voit D, Gupta JK, et al. Accuracy of hysteroscopy in the diagnosis of endometrial cancer and hyperplasia: a systematic quantitative review. JAMA. 2002;288(13):1610-21. [pmid: 12350192].
106 Clarke CE, Davies P. Systematic review of acute levodopa and apomorphine challenge tests in the diagnosis of idiopathic Parkinson's disease. J Neurol Neurosurg Psychiatry. 2000;69(5):590-4. [pmid: 11032609].
107 Clerico A, Fontana M, Zyw L, et al. Comparison of the diagnostic accuracy of brain natriuretic peptide (BNP) and the N-terminal part of the propeptide of BNP immunoassays in chronic and acute heart failure: a systematic review. Clin Chem. 2007;53(5):813-22. [pmid: 17384013].
108 Cnossen JS, Morris RK, ter Riet G, et al. Use of uterine artery Doppler ultrasonography to predict pre-eclampsia and intrauterine growth restriction: a systematic review and bivariable meta-analysis. CMAJ. 2008;178(6):701-11. [pmid: 18332385].
109 Cnossen JS, Vollebregt KC, de Vrieze N, et al. Accuracy of mean arterial pressure and blood pressure measurements in predicting pre-eclampsia: systematic review and meta-analysis. BMJ. 2008;336(7653):1117-20. [pmid: 18480117].
110 Colin C, Lanoir D, Touzet S, et al. Sensitivity and specificity of third-generation hepatitis C virus antibody detection assays: an analysis of the literature. J Viral Hepat. 2001;8(2):87-95. [pmid: 11264728].
111 Colli A, Fraquelli M, Casazza G, et al. Accuracy of ultrasonography, spiral CT, magnetic resonance, and alpha-fetoprotein in diagnosing hepatocellular carcinoma: a systematic review. Am J Gastroenterol. 2006;101(3):513-23. [pmid: 16542288].
112 Collins JA, Barnhart KT, Schlegel PN. Do sperm DNA integrity tests predict pregnancy with in vitro fertilization?. Fertil Steril. 2008;89(4):823-31. [pmid: 17644094].
113 Conde-Agudelo A, Kafury-Goeta AC. Triple-marker test as screening for Down syndrome: a meta-analysis. Obstet Gynecol Surv. 1998;53(6):369-76. [pmid: 9618713].
114 Conde-Agudelo A, Villar J, Lindheimer M. World Health Organization systematic review of screening tests for preeclampsia. Obstet Gynecol. 2004;104(6):1367-91. [pmid: 15572504].
115 Contopoulos-Ioannidis DG, Ioannidis JP. Maternal cell-free viremia in the natural history of perinatal HIV-1 transmission: a meta-analysis. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;18(2):126-35. [pmid: 9637577].
116 Cook DJ, Fitzgerald JM, Guyatt GH, et al. Evaluation of the protected brush catheter and bronchoalveolar lavage in the diagnosis of nosocomial pneumonia. J Intensive Care Med. 1991;6(4):196-205. [pmid: 10147949].
117 Cook RL, Hutchison SL, Ostergaard L, et al. Systematic review: noninvasive testing for Chlamydia trachomatis and Neisseria gonorrhoeae. Ann Intern Med. 2005;142(11):914-25. [pmid: 15941699].
118 Cooke G, Doust J, Sanders S. Is pulse palpation helpful in detecting atrial fibrillation? A systematic review. J Fam Pract. 2006;55(2):130-4. [pmid: 16451780].
119 Cote AM, Brown MA, Lam E, et al. Diagnostic accuracy of urinary spot protein:creatinine ratio for proteinuria in hypertensive pregnant women: systematic review. BMJ. 2008;336(7651):1003-6. [pmid: 18403498].
120 Coutance G, Le Page O, Lo T, et al. Prognostic value of brain natriuretic peptide in acute pulmonary embolism. Crit Care. 2008;12(4):R109. [pmid: 18721456].
121 Crane JM. Factors predicting labor induction success: a critical analysis. Clin Obstet Gynecol. 2006;49(3):573-84. [pmid: 16885664].
122 Crane JM, Hutchens D. Transvaginal sonographic measurement of cervical length to predict preterm birth in asymptomatic women at increased risk: a systematic review. Ultrasound Obstet Gynecol. 2008;31(5):579-87. [pmid: 18412093].
123 Crawford R, Walley G, Bridgman S, et al. Magnetic resonance imaging versus arthroscopy in the diagnosis of knee pathology, concentrating on meniscal lesions and ACL tears: a systematic review. Br Med Bull. 2007;84:5-23. [pmid: 17785279].
124 Cremonini F, Wise J, Moayyedi P, et al. Diagnostic and therapeutic use of proton pump inhibitors in non-cardiac chest pain: a metaanalysis. Am J Gastroenterol. 2005;100(6):1226-32. [pmid: 15929749].
125 Critchley J, Bates I. Haemoglobin colour scale for anaemia diagnosis where there is no laboratory: a systematic review. Int J Epidemiol. 2005;34(6):1425-34. [pmid: 16199438].
126 Crobach MJ, Dekkers OM, Wilcox MH, et al. European Society of Clinical Microbiology and Infectious Diseases (ESCMID): data review and recommendations for diagnosing Clostridium difficile-infection (CDI). Clin Microbiol Infect. 2009;15(12):1053-66. [pmid: 19929972].
127 Cronin P, Dwamena BA, Kelly AM, et al. Solitary pulmonary nodules and masses: a meta-analysis of the diagnostic utility of alternative imaging tests. Eur Radiol. 2008;18(9):1840-56. [pmid: 18607593].
128 Cronin P, Dwamena BA, Kelly AM, et al. Solitary pulmonary nodules: meta-analytic comparison of cross-sectional imaging modalities for diagnosis of malignancy. Radiology. 2008;246(3):772-82. [pmid: 18235105].
129 Cruciani M, Marcati P, Malena M, et al. Meta-analysis of diagnostic procedures for Pneumocystis carinii pneumonia in HIV-1-infected patients. Eur Respir J. 2002;20(4):982-9. [pmid: 12412693].
130 Cruciani M, Nardi S, Malena M, et al. Systematic review of the accuracy of the ParaSight-F test in the diagnosis of Plasmodium falciparum malaria. Med Sci Monit. 2004;10(7):MT81-8. [pmid: 15232515].
131 Cruciani M, Scarparo C, Malena M, et al. Meta-analysis of BACTEC MGIT 960 and BACTEC 460 TB, with or without solid media, for detection of mycobacteria. J Clin Microbiol. 2004;42(5):2321-5. [pmid: 15131224].
132 Cuckle H, van Oudgaarden ED, Mason G, et al. Taking account of vaginal bleeding in screening for Down's syndrome. Br J Obstet Gynaecol. 1994;101(11):948-53. [pmid: 7528053].
133 Cueto SM, Cavanaugh SH, Benenson RS, et al. Computed tomography scan versus ventilation-perfusion lung scan in the detection of pulmonary embolism. J Emerg Med. 2001;21(2):155-64. [pmid: 11489406].
134 Curvers WL, van den Broek FJ, Reitsma JB, et al. Systematic review of narrow-band imaging for the detection and differentiation of abnormalities in the esophagus and stomach (with video). Gastrointest Endosc. 2009;69(2):307-17. [pmid: 19185690].
135 Cury RC, Feutchner G, Pena CS, et al. Acute chest pain imaging in the emergency department with cardiac computed tomography angiography. J Nucl Cardiol. 2008;15(4):564-75. [pmid: 18674724].
136 Cuzick J, Arbyn M, Sankaranarayanan R, et al. Overview of human papillomavirus-based and other novel options for cervical cancer screening in developed and developing countries. Vaccine. Suppl 10. 2008;26:K29-41. [pmid: 18847555].
137 Cuzick J, Clavel C, Petry KU, et al. Overview of the European and North American studies on HPV testing in primary cervical cancer screening. Int J Cancer. 2006;119(5):1095-101. [pmid: 16586444].
138 Dales RE, Stark RM, Raman S. Computed tomography to stage lung cancer. Approaching a controversy using meta-analysis. Am Rev Respir Dis. 1990;141(5 Pt 1):1096-101. [pmid: 2160211].
139 Daley P, Thomas S, Pai M. Nucleic acid amplification tests for the diagnosis of tuberculous lymphadenitis: a systematic review. Int J Tuberc Lung Dis. 2007;11(11):1166-76. [pmid: 17958977].
140 Danias PG, Roussakis A, Ioannidis JP. Diagnostic performance of coronary magnetic resonance angiography as compared against conventional X-ray angiography: a meta-analysis. J Am Coll Cardiol. 2004;44(9):1867-76. [pmid: 15519021].
141 D'Arcy CA, McGee S. The rational clinical examination. Does this patient have carpal tunnel syndrome?. JAMA. 2000;283(23):3110-7. [pmid: 10865306].
142 Davison SP, Clifton MS, Kauffman L, et al. Sentinel node biopsy for the detection of head and neck melanoma: a review. Ann Plast Surg. 2001;47(2):206-11. [pmid: 11506334].
143 de Albuquerque Fonseca L, Picano E. Comparison of dipyridamole and exercise stress echocardiography for detection of coronary artery disease (a meta-analysis). Am J Cardiol. 2001;87(10):1193-6. A4. [pmid: 11356397].
144 De Bernardinis M, Violi V, Roncoroni L, et al. Discriminant power and information content of Ranson's prognostic signs in acute pancreatitis: a meta-analytic study. Crit Care Med. 1999;27(10):2272-83. [pmid: 10548220].
145 de Bondt RB, Nelemans PJ, Hofman PA, et al. Detection of lymph node metastases in head and neck cancer: a meta-analysis comparing US, USgFNAC, CT and MR imaging. Eur J Radiol. 2007;64(2):266-72. [pmid: 17391885].
146 de Bruyn G, Graviss EA. A systematic review of the diagnostic accuracy of physical examination for the detection of cirrhosis. BMC Med Inform Decis Mak. 2001;1:6. [pmid: 11806763].
147 de Jaeger A, Litalien C, Lacroix J, et al. Protected specimen brush or bronchoalveolar lavage to diagnose bacterial nosocomial pneumonia in ventilated adults: a meta-analysis. Crit Care Med. 1999;27(11):2548-60. [pmid: 10579279].
148 de Jesus JO, Parker L, Frangos AJ, et al. Accuracy of MRI, MR arthrography, and ultrasound in the diagnosis of rotator cuff tears: a meta-analysis. AJR Am J Roentgenol. 2009;192(6):1701-7. [pmid: 19457838].
149 de Kroon CD, de Bock GH, Dieben SW, et al. Saline contrast hysterosonography in abnormal uterine bleeding: a systematic review and meta-analysis. BJOG. 2003;110(10):938-47. [pmid: 14550365].
150 de Lorijn F, Kremer LC, Reitsma JB, et al. Diagnostic tests in Hirschsprung disease: a systematic review. J Pediatr Gastroenterol Nutr. 2006;42(5):496-505. [pmid: 16707970].
151 de Sousa MR, Morillo CA, Rabelo FT, et al. Non-sustained ventricular tachycardia as a predictor of sudden cardiac death in patients with left ventricular dysfunction: a meta-analysis. Eur J Heart Fail. 2008;10(10):1007-14. [pmid: 18692437].
152 de Vries SO, Hunink MG, Polak JF. Summary receiver operating characteristic curves as a technique for meta-analysis of the diagnostic performance of duplex ultrasonography in peripheral arterial disease. Acad Radiol. 1996;3(4):361-9. [pmid: 8796687].
153 Debrey SM, Yu H, Lynch JK, et al. Diagnostic accuracy of magnetic resonance angiography for internal carotid artery disease: a systematic review and meta-analysis. Stroke. 2008;39(8):2237-48. [pmid: 18556586].
154 Delgado-Bolton RC, Fernandez-Perez C, Gonzalez-Mate A, et al. Meta-analysis of the performance of 18F-FDG PET in primary tumor detection in unknown primary tumors. J Nucl Med. 2003;44(8):1301-14. [pmid: 12902422].
155 Denham DW, Norman J. Cost-effectiveness of preoperative sestamibi scan for primary hyperparathyroidism is dependent solely upon the surgeon's choice of operative procedure. J Am Coll Surg. 1998;186(3):293-305. [pmid: 9510260].
156 Des Guetz G, Uzzan B, Nicolas P, et al. Is sentinel lymph node mapping in colorectal cancer a future prognostic factor? A meta-analysis. World J Surg. 2007;31(6):1304-12. [pmid: 17460811].
157 Detrano R, Gianrossi R, Mulvihill D, et al. Exercise-induced ST segment depression in the diagnosis of multivessel coronary disease: a meta analysis. J Am Coll Cardiol. 1989;14(6):1501-8. [pmid: 2809010].
158 Detrano R, Janosi A, Lyons KP, et al. Factors affecting sensitivity and specificity of a diagnostic test: the exercise thallium scintigram. Am J Med. 1988;84(4):699-710. [pmid: 3041808].
159 Detsky ME, McDonald DR, Baerlocher MO, et al. Does this patient with headache have a migraine or need neuroimaging?. JAMA. 2006;296(10):1274-83. [pmid: 16968852].
160 Deville WL, van der Windt DA, Dzaferagic A, et al. The test of Lasegue: systematic review of the accuracy in diagnosing herniated discs. Spine (Phila Pa 1976). 2000;25(9):1140-7. [pmid: 10788860].
161 Deville WL, Yzermans JC, van Duijn NP, et al. The urine dipstick test useful to rule out infections. A meta-analysis of the accuracy. BMC Urol. 2004;4:4. [pmid: 15175113].
162 Devous MD Sr., Thisted RA, Morgan GF, et al. SPECT brain imaging in epilepsy: a meta-analysis. J Nucl Med. 1998;39(2):285-93. [pmid: 9476937].
163 Di Fabio RP. Meta-analysis of the sensitivity and specificity of platform posturography. Arch Otolaryngol Head Neck Surg. 1996;122(2):150-6. [pmid: 8630208].
164 Di Nisio M, Squizzato A, Rutjes AW, et al. Diagnostic accuracy of D-dimer test for exclusion of venous thromboembolism: a systematic review. J Thromb Haemost. 2007;5(2):296-304. [pmid: 17155963].
165 Di Tanna GL, Berti E, Stivanello E, et al. Informative value of clinical research on multislice computed tomography in the diagnosis of coronary artery disease: A systematic review. Int J Cardiol. 2008;130(3):386-404. [pmid: 18760849].
166 Dijkhuizen FP, Mol BW, Brolmann HA, et al. The accuracy of endometrial sampling in the diagnosis of patients with endometrial carcinoma and hyperplasia: a meta-analysis. Cancer. 2000;89(8):1765-72. [pmid: 11042572].
167 Dinh MT, Abad CL, Safdar N. Diagnostic accuracy of the physical examination and imaging tests for osteomyelitis underlying diabetic foot ulcers: meta-analysis. Clin Infect Dis. 2008;47(4):519-27. [pmid: 18611152].
168 Dinis-Ribeiro M, Yamaki G, Miki K, et al. Meta-analysis on the validity of pepsinogen test for gastric carcinoma, dysplasia or chronic atrophic gastritis screening. J Med Screen. 2004;11(3):141-7. [pmid: 15333273].
169 Dinnes J, Deeks J, Kunst H, et al. A systematic review of rapid diagnostic tests for the detection of tuberculosis infection. Health Technol Assess. 2007;11(3):1-196. [pmid: 17266837].
170 Dodd SR, Lancaster GA, Craig JV, et al. In a systematic review, infrared ear thermometry for fever diagnosis in children finds poor sensitivity. J Clin Epidemiol. 2006;59(4):354-7. [pmid: 16549256].
171 Dong MJ, Liu ZF, Zhao K, et al. Value of 18F-FDG-PET/PET-CT in differentiated thyroid carcinoma with radioiodine-negative whole-body scan: a meta-analysis. Nucl Med Commun. 2009;30(8):639-50. [pmid: 19512954].
172 Dong MJ, Zhao K, Lin XT, et al. Role of fluorodeoxyglucose-PET versus fluorodeoxyglucose-PET/computed tomography in detection of unknown primary tumor: a meta-analysis of the literature. Nucl Med Commun. 2008;29(9):791-802. [pmid: 18677207].
173 Doobay AV, Anand SS. Sensitivity and specificity of the ankle-brachial index to predict future cardiovascular outcomes: a systematic review. Arterioscler Thromb Vasc Biol. 2005;25(7):1463-9. [pmid: 15879302].
174 Doria AS, Moineddin R, Kellenberger CJ, et al. US or CT for Diagnosis of Appendicitis in Children and Adults? A Meta-Analysis. Radiology. 2006;241(1):83-94. [pmid: 16928974].
175 Dougall NJ, Bruggink S, Ebmeier KP. Systematic review of the diagnostic accuracy of 99mTc-HMPAO-SPECT in dementia. Am J Geriatr Psychiatry. 2004;12(6):554-70. [pmid: 15545324].
176 Doust JA, Glasziou PP, Pietrzak E, et al. A systematic review of the diagnostic accuracy of natriuretic peptides for heart failure. Arch Intern Med. 2004;164(18):1978-84. [pmid: 15477431].
177 Dove SB. Radiographic diagnosis of dental caries. J Dent Educ. 2001;65(10):985-90. [pmid: 11700001].
178 Dowling S, Spooner CH, Liang Y, et al. Accuracy of Ottawa Ankle Rules to exclude fractures of the ankle and midfoot in children: a meta-analysis. Acad Emerg Med. 2009;16(4):277-87. [pmid: 19187397].
179 Downer MC, Moles DR, Palmer S, et al. A systematic review of test performance in screening for oral cancer and precancer. Oral Oncol. 2004;40(3):264-73. [pmid: 14747057].
180 Dubin MG, Ebert CS, Coffey CS, et al. Concordance of middle meatal swab and maxillary sinus aspirate in acute and chronic sinusitis: a meta-analysis. Am J Rhinol. 2005;19(5):462-70. [pmid: 16270600].
181 Dumler JS. Molecular diagnosis of Lyme disease: review and meta-analysis. Mol Diagn. 2001;6(1):1-11. [pmid: 11257206].
182 Dwamena BA, Sonnad SS, Angobaldo JO, et al. Metastases from non-small cell lung cancer: mediastinal staging in the 1990s—meta-analytic comparison of PET and CT. Radiology. 1999;213(2):530-6. [pmid: 10551237].
183 East JE, Tan EK, Bergman JJ, et al. Meta-analysis: narrow band imaging for lesion characterization in the colon, oesophagus, duodenal ampulla and lung. Aliment Pharmacol Ther. 2008;28(7):854-67. [pmid: 18637003].
184 Ebell MH, Flewelling D, Flynn CA. A systematic review of troponin T and I for diagnosing acute myocardial infarction. J Fam Pract. 2000;49(6):550-6. [pmid: 10923557].
185 Ebell MH, White LL, Casault T. A systematic review of the history and physical examination to diagnose influenza. J Am Board Fam Pract. 2004;17(1):1-5. [pmid: 15014046].
186 Ebell MH, White LL, Weismantel D. A systematic review of troponin T and I values as a prognostic tool for patients with chest pain. J Fam Pract. 2000;49(8):746-53. [pmid: 10947143].
187 Eiberg JP, Lundorf E, Thomsen C, et al. Peripheral vascular surgery and magnetic resonance arteriography—a review. Eur J Vasc Endovasc Surg. 2001;22(5):396-402. [pmid: 11735175].
188 Elamin MB, Murad MH, Mullan R, et al. Accuracy of diagnostic tests for Cushing's syndrome: a systematic review and metaanalyses. J Clin Endocrinol Metab. 2008;93(5):1553-62. [pmid: 18334594].
189 Engelbrecht MR, Jager GJ, Laheij RJ, et al. Local staging of prostate cancer using magnetic resonance imaging: a meta-analysis. Eur Radiol. 2002;12(9):2294-302. [pmid: 12195484].
190 Engels EA, Terrin N, Barza M, et al. Meta-analysis of diagnostic tests for acute sinusitis. J Clin Epidemiol. 2000;53(8):852-62. [pmid: 10942869].
191 Engman ML. An update on EBCT (Ultrafast CT) scans for coronary artery disease. J Insur Med. 1998;30(3):175-9. [pmid: 10351178].
192 Eustatia-Rutten CF, Smit JW, Romijn JA, et al. Diagnostic value of serum thyroglobulin measurements in the follow-up of differentiated thyroid carcinoma, a structured meta-analysis. Clin Endocrinol (Oxf). 2004;61(1):61-74. [pmid: 15212646].
193 Evennett N, Alexander N, Petrov M, et al. A systematic review of serologic tests in the diagnosis of necrotizing enterocolitis. J Pediatr Surg. 2009;44(11):2192-201. [pmid: 19944232].
194 Evennett NJ, Petrov MS, Mittal A, et al. Systematic review and pooled estimates for the diagnostic accuracy of serological markers for intestinal ischemia. World J Surg. 2009;33(7):1374-83. [pmid: 19424744].
195 Ewald B, Attia J. Which test to detect microalbuminuria in diabetic patients? A systematic review. Aust Fam Physician. 2004;33(7):565-7. 71. [pmid: 15301181].
196 Ewald B, Ewald D, Thakkinstian A, et al. Meta-analysis of B type natriuretic peptide and N-terminal pro B natriuretic peptide in the diagnosis of clinical heart failure and population screening for left ventricular systolic dysfunction. Intern Med J. 2008;38(2):101-13. [pmid: 18290826].
197 Fahey MT, Irwig L, Macaskill P. Meta-analysis of Pap test accuracy. Am J Epidemiol. 1995;141(7):680-9. [pmid: 7702044].
198 Falagas ME, Kazantzi MS, Bliziotis IA. Comparison of utility of blood cultures from intravascular catheters and peripheral veins: a systematic review and decision analysis. J Med Microbiol. 2008;57(Pt 1):1-8. [pmid: 18065660].
199 Falk G, Fahey T. C-reactive protein and community-acquired pneumonia in ambulatory care: systematic review of diagnostic accuracy studies. Fam Pract. 2009;26(1):10-21. [pmid: 19074757].
200 Fancher TL, White RH, Kravitz RL. Combined use of rapid D-dimer testing and estimation of clinical probability in the diagnosis of deep vein thrombosis: systematic review. BMJ. 2004;329(7470):821. [pmid: 15383452].
201 Faron G, Boulvain M, Irion O, et al. Prediction of preterm delivery by fetal fibronectin: a meta-analysis. Obstet Gynecol. 1998;92(1):153-8. [pmid: 9649113].
202 Farquhar C, Ekeroma A, Furness S, et al. A systematic review of transvaginal ultrasonography, sonohysterography and hysteroscopy for the investigation of abnormal uterine bleeding in premenopausal women. Acta Obstet Gynecol Scand. 2003;82(6):493-504. [pmid: 12780419].
203 Farrell T, Chien PF, Gordon A. Intrapartum umbilical artery Doppler velocimetry as a predictor of adverse perinatal outcome: a systematic review. Br J Obstet Gynaecol. 1999;106(8):783-92. [pmid: 10453827].
204 Feng Y, Schlosser FJ, Sumpio BE. The Semmes Weinstein monofilament examination as a screening tool for diabetic peripheral neuropathy. J Vasc Surg. 2009;50(3):675-82. 82 e1. [pmid: 19595541].
205 Fernandez Alvarez JR, Amess PN, Gandhi RS, et al. Diagnostic value of subependymal pseudocysts and choroid plexus cysts on neonatal cerebral ultrasound: a meta-analysis. Arch Dis Child Fetal Neonatal Ed. 2009;94(6):F443-6. [pmid: 19321510].
206 Fischer BM, Mortensen J, Hojgaard L. Positron emission tomography in the diagnosis and staging of lung cancer: a systematic, quantitative review. Lancet Oncol. 2001;2(11):659-66. [pmid: 11902536].
207 Fleischmann KE, Hunink MG, Kuntz KM, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. 1998;280(10):913-20. [pmid: 9739977].
208 Flood RG, Badik J, Aronoff SC. The utility of serum C-reactive protein in differentiating bacterial from nonbacterial pneumonia in children: a meta-analysis of 1230 children. Pediatr Infect Dis J. 2008;27(2):95-9. [pmid: 18174874].
209 Flores LL, Pai M, Colford JM Jr., et al. In-house nucleic acid amplification tests for the detection of Mycobacterium tuberculosis in sputum specimens: meta-analysis and meta-regression. BMC Microbiol. 2005;5:55. [pmid: 16202138].
210 Ford AC, Chey WD, Talley NJ, et al. Yield of diagnostic tests for celiac disease in individuals with symptoms suggestive of irritable bowel syndrome: systematic review and meta-analysis. Arch Intern Med. 2009;169(7):651-8. [pmid: 19364994].
211 Ford AC, Ching E, Moayyedi P. Meta-analysis: yield of diagnostic tests for coeliac disease in dyspepsia. Aliment Pharmacol Ther. 2009;30(1):28-36. [pmid: 19416130].
212 Ford AC, Spiegel BM, Talley NJ, et al. Small intestinal bacterial overgrowth in irritable bowel syndrome: systematic review and meta-analysis. Clin Gastroenterol Hepatol. 2009;7(12):1279-86. [pmid: 19602448].
213 Ford AC, Veldhuyzen van Zanten SJ, Rodgers CC, et al. Diagnostic utility of alarm features for colorectal cancer: systematic review and meta-analysis. Gut. 2008;57(11):1545-53. [pmid: 18676420].
214 Fraile M, Rull M, Julian FJ, et al. Sentinel node biopsy as a practical alternative to axillary lymph node dissection in breast cancer patients: an approach to its validity. Ann Oncol. 2000;11(6):701-5. [pmid: 10942059].
215 Fransen GA, Janssen MJ, Muris JW, et al. Meta-analysis: the diagnostic value of alarm symptoms for upper gastrointestinal malignancy. Aliment Pharmacol Ther. 2004;20(10):1045-52. [pmid: 15569106].
216 Fraquelli M, Colli A, Casazza G, et al. Role of US in detection of Crohn disease: meta-analysis. Radiology. 2005;236(1):95-101. [pmid: 15987966].
217 Friedrich-Rust M, Ong MF, Martens S, et al. Performance of transient elastography for the staging of liver fibrosis: a meta-analysis. Gastroenterology. 2008;134(4):960-74. [pmid: 18395077].
218 Gao H, McDonnell A, Harrison DA, et al. Systematic review and evaluation of physiological track and trigger warning systems for identifying at-risk patients on the ward. Intensive Care Med. 2007;33(4):667-79. [pmid: 17318499].
219 Garrow D, Miller S, Sinha D, et al. Endoscopic ultrasound: a meta-analysis of test performance in suspected biliary obstruction. Clin Gastroenterol Hepatol. 2007;5(5):616-23. [pmid: 17478348].
220 Garzon PP, Eisenberg MJ. Functional testing for the detection of restenosis after percutaneous transluminal coronary angioplasty: a meta-analysis. Can J Cardiol. 2001;17(1):41-8. [pmid: 11173313].
221 Geersing GJ, Janssen KJ, Oudega R, et al. Excluding venous thromboembolism using point of care D-dimer tests in outpatients: a diagnostic meta-analysis. BMJ. 2009;339:b2990. [pmid: 19684102].
222 Gehi AK, Stein RH, Metz LD, et al. Microvolt T-wave alternans for the risk stratification of ventricular tachyarrhythmic events: a meta-analysis. J Am Coll Cardiol. 2005;46(1):75-82. [pmid: 15992639].
223 Geisser ME, Ranavaya M, Haig AJ, et al. A meta-analytic review of surface electromyography among persons with low back pain and normal, healthy controls. J Pain. 2005;6(11):711-26. [pmid: 16275595].
224 Geleijnse ML, Krenning BJ, Soliman OI, et al. Dobutamine stress echocardiography for the detection of coronary artery disease in women. Am J Cardiol. 2007;99(5):714-7. [pmid: 17317379].
225 Geleijnse ML, Krenning BJ, van Dalen BM, et al. Factors affecting sensitivity and specificity of diagnostic testing: dobutamine stress echocardiography. J Am Soc Echocardiogr. 2009;22(11):1199-208. [pmid: 19766453].
226 Geomini P, Bremer G, Kruitwagen R, et al. Diagnostic accuracy of frozen section diagnosis of the adnexal mass: a metaanalysis. Gynecol Oncol. 2005;96(1):1-9. [pmid: 15589572].
227 Gerdes LU, Jorgensen PE, Nexo E, et al. C-reactive protein and bacterial meningitis: a meta-analysis. Scand J Clin Lab Invest. 1998;58(5):383-93. [pmid: 9819187].
228 Gianrossi R, Detrano R, Colombo A, et al. Cardiac fluoroscopy for the diagnosis of coronary artery disease: a meta analytic review. Am Heart J. 1990;120(5):1179-88. [pmid: 2146867].
229 Gibreel A, Maheshwari A, Bhattacharya S, et al. Ultrasound tests of ovarian reserve; a systematic review of accuracy in predicting fertility outcomes. Hum Fertil (Camb). 2009;12(2):95-106. [pmid: 19802960].
230 Gilbody S, Richards D, Brealey S, et al. Screening for depression in medical settings with the Patient Health Questionnaire (PHQ): a diagnostic meta-analysis. J Gen Intern Med. 2007;22(11):1596-602. [pmid: 17874169].
231 Gill CJ, Lau J, Gorbach SL, et al. Diagnostic accuracy of stool assays for inflammatory bacterial gastroenteritis in developed and resource-poor countries. Clin Infect Dis. 2003;37(3):365-75. [pmid: 12884161].
232 Gisbert JP, Abraira V. Accuracy of Helicobacter pylori diagnostic tests in patients with bleeding peptic ulcer: a systematic review and meta-analysis. Am J Gastroenterol. 2006;101(4):848-63. [pmid: 16494583].
233 Gisbert JP, de la Morena F, Abraira V. Accuracy of monoclonal stool antigen test for the diagnosis of H. pylori infection: a systematic review and meta-analysis. Am J Gastroenterol. 2006;101(8):1921-30. [pmid: 16780557].
234 Gisbert JP, Pajares JM. Diagnosis of Helicobacter pylori infection by stool antigen determination: a systematic review. Am J Gastroenterol. 2001;96(10):2829-38. [pmid: 11693315].
235 Gisbert JP, Pajares JM. Stool antigen test for the diagnosis of Helicobacter pylori infection: a systematic review. Helicobacter. 2004;9(4):347-68. [pmid: 15270750].
236 Glas AS, Roos D, Deutekom M, et al. Tumor markers in the diagnosis of primary bladder cancer. A systematic review. J Urol. 2003;169(6):1975-82. [pmid: 12771702].
237 Goldstein LB, Simel DL. Is this patient having a stroke?. JAMA. 2005;293(19):2391-402. [pmid: 15900010].
238 Goodacre S, Sampson FC, Sutton AJ, et al. Variation in the diagnostic performance of D-dimer for suspected deep vein thrombosis. QJM. 2005;98(7):513-27. [pmid: 15955795].
239 Goodacre S, Sutton AJ, Sampson FC. Meta-analysis: The value of clinical assessment in the diagnosis of deep venous thrombosis. Ann Intern Med. 2005;143(2):129-39. [pmid: 16027455].
240 Goodman CM, Cohen V, Thornby J, et al. The life span of silicone gel breast implants and a comparison of mammography, ultrasonography, and magnetic resonance imaging in detecting implant rupture: a meta-analysis. Ann Plast Surg. 1998;41(6):577-85. discussion 85-6. [pmid: 9869129].
241 Goodman CS, Hur JY, Adajar MA, et al. How well does CT predict the need for laparotomy in hemodynamically stable patients with penetrating abdominal injury? A review and meta-analysis. AJR Am J Roentgenol. 2009;193(2):432-7. [pmid: 19620440].
242 Goonetilleke KS, Siriwardena AK. Systematic review of carbohydrate antigen (CA 19-9) as a biochemical marker in the diagnosis of pancreatic cancer. Eur J Surg Oncol. 2007;33(3):266-70. [pmid: 17097848].
243 Gordon I, Barkovics M, Pindoria S, et al. Primary vesicoureteric reflux as a predictor of renal damage in children hospitalized with urinary tract infection: a systematic review and meta-analysis. J Am Soc Nephrol. 2003;14(3):739-44. [pmid: 12595511].
244 Gorelick MH, Shaw KN. Screening tests for urinary tract infection in children: A meta-analysis. Pediatrics. 1999;104(5):e54. [pmid: 10545580].
245 Goto M, Noguchi Y, Koyama H, et al. Diagnostic value of adenosine deaminase in tuberculous pleural effusion: a meta-analysis. Ann Clin Biochem. 2003;40(Pt 4):374-81. [pmid: 12880538].
246 Gottlieb RH, Widjaja J, Tian L, et al. Calf sonography for detecting deep venous thrombosis in symptomatic patients: experience and review of the literature. J Clin Ultrasound. 1999;27(8):415-20. [pmid: 10477882].
247 Gould MK, Kuschner WG, Rydzak CE, et al. Test performance of positron emission tomography and computed tomography for mediastinal staging in patients with non-small-cell lung cancer: a meta-analysis. Ann Intern Med. 2003;139(11):879-92. [pmid: 14644890].
248 Gould MK, Maclean CC, Kuschner WG, et al. Accuracy of positron emission tomography for diagnosis of pulmonary nodules and mass lesions: a meta-analysis. JAMA. 2001;285(7):914-24. [pmid: 11180735].
249 Greco S, Girardi E, Masciangelo R, et al. Adenosine deaminase and interferon gamma measurements for the diagnosis of tuberculous pleurisy: a meta-analysis. Int J Tuberc Lung Dis. 2003;7(8):777-86. [pmid: 12921155].
250 Greco S, Rulli M, Girardi E, et al. Diagnostic accuracy of in-house PCR for pulmonary tuberculosis in smear-positive patients: meta-analysis and metaregression. J Clin Microbiol. 2009;47(3):569-76. [pmid: 19144797].
251 Gross SJ, Shulman LP, Tolley EA, et al. Isolated fetal choroid plexus cysts and trisomy 18: a review and meta-analysis. Am J Obstet Gynecol. 1995;172(1 Pt 1):83-7. [pmid: 7847564].
252 Gu P, Huang G, Chen Y, et al. Diagnostic utility of pleural fluid carcinoembryonic antigen and CYFRA 21-1 in patients with pleural effusion: a systematic review and meta-analysis. J Clin Lab Anal. 2007;21(6):398-405. [pmid: 18022924].
253 Gu P, Pan LL, Wu SQ, et al. CA 125, PET alone, PET-CT, CT and MRI in diagnosing recurrent ovarian carcinoma: a systematic review and meta-analysis. Eur J Radiol. 2009;71(1):164-74. [pmid: 18378417].
254 Gu P, Zhao YZ, Jiang LY, et al. Endobronchial ultrasound-guided transbronchial needle aspiration for staging of lung cancer: a systematic review and meta-analysis. Eur J Cancer. 2009;45(8):1389-96. [pmid: 19124238].
255 Gupta R, Dastane AM, McKenna R Jr., et al. The predictive value of epidermal growth factor receptor tests in patients with pulmonary adenocarcinoma: review of current “best evidence” with meta-analysis. Hum Pathol. 2009;40(3):356-65. [pmid: 18976796].
256 Haase M, Bellomo R, Devarajan P, et al. Accuracy of neutrophil gelatinase-associated lipocalin (NGAL) in diagnosis and prognosis in acute kidney injury: a systematic review and meta-analysis. Am J Kidney Dis. 2009;54(6):1012-24. [pmid: 19850388].
257 Hajdinjak T. UroVysion FISH test for detecting urothelial cancers: meta-analysis of diagnostic accuracy and comparison with urinary cytology testing. Urol Oncol. 2008;26(6):646-51. [pmid: 18367109].
258 Halfon P, Munteanu M, Poynard T. FibroTest-ActiTest as a non-invasive marker of liver fibrosis. Gastroenterol Clin Biol. 2008;32(6 Suppl 1):22-39. [pmid: 18973844].
259 Hallan S, Asberg A. The accuracy of C-reactive protein in diagnosing acute appendicitis—a meta-analysis. Scand J Clin Lab Invest. 1997;57(5):373-80. [pmid: 9279962].
260 Halligan S, Altman DG, Taylor SA, et al. CT colonography in the detection of colorectal polyps and cancer: systematic review, meta-analysis, and proposed minimum data set for study level reporting. Radiology. 2005;237(3):893-904. [pmid: 16304111].
261 Hamon M, Biondi-Zoccai GG, Malagutti P, et al. Diagnostic performance of multislice spiral computed tomography of coronary arteries as compared with conventional invasive coronary angiography: a meta-analysis. J Am Coll Cardiol. 2006;48(9):1896-910. [pmid: 17084268].
262 Hamon M, Champ-Rigot L, Morello R, et al. Diagnostic accuracy of in-stent coronary restenosis detection with multislice spiral computed tomography: a meta-analysis. Eur Radiol. 2008;18(2):217-25. [pmid: 17763854].
263 Hamon M, Lepage O, Malagutti P, et al. Diagnostic performance of 16- and 64-section spiral CT for coronary artery bypass graft assessment: meta-analysis. Radiology. 2008;247(3):679-86. [pmid: 18403629].
264 Hamon M, Morello R, Riddell JW. Coronary arteries: diagnostic performance of 16-versus 64-section spiral CT compared with invasive coronary angiography—meta-analysis. Radiology. 2007;245(3):720-31. [pmid: 17951354].
265 Hancock MJ, Maher CG, Latimer J, et al. Systematic review of tests to identify the disc, SIJ or facet joint as the source of low back pain. Eur Spine J. 2007;16(10):1539-50. [pmid: 17566796].
266 Harvey P, Basuita A, Endersby D, et al. A systematic review of the diagnostic accuracy of prostate specific antigen. BMC Urol. 2009;9:14. [pmid: 19744336].
267 Harvey RT, Gefter WB, Hrung JM, et al. Accuracy of CT angiography versus pulmonary angiography in the diagnosis of acute pulmonary embolism: evaluation of the literature with summary ROC curve analysis. Acad Radiol. 2000;7(10):786-97. [pmid: 11048876].
268 Hatfield AS, Sanchez-Ramos L, Kaunitz AM. Sonographic cervical assessment to predict the success of labor induction: a systematic review with metaanalysis. Am J Obstet Gynecol. 2007;197(2):186-92. [pmid: 17689645].
269 Hayashino Y, Goto M, Noguchi Y, et al. Ventilation-perfusion scanning and helical CT in suspected pulmonary embolism: meta-analysis of diagnostic performance. Radiology. 2005;234(3):740-8. [pmid: 15734930].
270 Hegedus EJ, Cook C, Hasselblad V, et al. Physical examination tests for assessing a torn meniscus in the knee: a systematic review with meta-analysis. J Orthop Sports Phys Ther. 2007;37(9):541-50. [pmid: 17939613].
271 Hegedus EJ, Goode A, Campbell S, et al. Physical examination tests of the shoulder: a systematic review with meta-analysis of individual tests. Br J Sports Med. 2008;42(2):80-92. discussion. [pmid: 17720798].
272 Heijenbrok-Kal MH, Fleischmann KE, Hunink MG. Stress echocardiography, stress single-photon-emission computed tomography and electron beam computed tomography for the assessment of coronary artery disease: a meta-analysis of diagnostic performance. Am Heart J. 2007;154(3):415-23. [pmid: 17719283].
273 Heijenbrok-Kal MH, Kock MC, Hunink MG. Lower extremity arterial disease: multidetector CT angiography meta-analysis. Radiology. 2007;245(2):433-9. [pmid: 17848679].
274 Heim SW, Schectman JM, Siadaty MS, et al. D-dimer testing for deep venous thrombosis: a metaanalysis. Clin Chem. 2004;50(7):1136-47. [pmid: 15142977].
275 Helbert M, Bodger S, Cavenagh J, et al. Optimising testing for phospholipid antibodies. J Clin Pathol. 2001;54(9):693-8. [pmid: 11533076].
276 Hendriks DJ, Kwee J, Mol BW, et al. Ultrasonography as a tool for the prediction of outcome in IVF patients: a comparative meta-analysis of ovarian volume and antral follicle count. Fertil Steril. 2007;87(4):764-75. [pmid: 17239869].
277 Hendriks DJ, Mol BW, Bancsi LF, et al. Antral follicle count in the prediction of poor ovarian response and pregnancy after in vitro fertilization: a meta-analysis and comparison with basal follicle-stimulating hormone level. Fertil Steril. 2005;83(2):291-301. [pmid: 15705365].
278 Henschke N, Maher CG, Refshauge KM. Screening for malignancy in low back pain patients: a systematic review. Eur Spine J. 2007;16(10):1673-9. [pmid: 17566791].
279 Hobby JL, Tom BD, Bearcroft PW, et al. Magnetic resonance imaging of the wrist: diagnostic performance statistics. Clin Radiol. 2001;56(1):50-7. [pmid: 11162698].
280 Hoffman RM, Clanon DL, Littenberg B, et al. Using the free-to-total prostate-specific antigen ratio to detect prostate cancer in men with nonspecific elevations of prostate-specific antigen levels. J Gen Intern Med. 2000;15(10):739-48. [pmid: 11089718].
281 Hofman PA, Nelemans P, Kemerink GJ, et al. Value of radiological diagnosis of skull fracture in the management of mild head injury: meta-analysis. J Neurol Neurosurg Psychiatry. 2000;68(4):416-22. [pmid: 10727475].
282 Hogg K, Brown G, Dunning J, et al. Diagnosis of pulmonary embolism with CT pulmonary angiography: a systematic review. Emerg Med J. 2006;23(3):172-8. [pmid: 16498151].
283 Holmes JF, Akkinepalli R. Computed tomography versus plain radiography to screen for cervical spine injury: a meta-analysis. J Trauma. 2005;58(5):902-5. [pmid: 15920400].
284 Holmes JF, Gladman A, Chang CH. Performance of abdominal ultrasonography in pediatric blunt trauma patients: a meta-analysis. J Pediatr Surg. 2007;42(9):1588-94. [pmid: 17848254].
285 Holroyd-Leduc JM, Tannenbaum C, Thorpe KE, et al. What type of urinary incontinence does this woman have?. JAMA. 2008;299(12):1446-56. [pmid: 18364487].
286 Holty JE, Kuschner WG, Gould MK. Accuracy of transbronchial needle aspiration for mediastinal staging of non-small cell lung cancer: a meta-analysis. Thorax. 2005;60(11):949-55. [pmid: 15994251].
287 Honest H, Bachmann LM, Coomarasamy A, et al. Accuracy of cervical transvaginal sonography in predicting preterm birth: a systematic review. Ultrasound Obstet Gynecol. 2003;22(3):305-22. [pmid: 12942506].
288 Honest H, Bachmann LM, Gupta JK, et al. Accuracy of cervicovaginal fetal fibronectin test in predicting risk of spontaneous preterm birth: systematic review. BMJ. 2002;325(7359):301. [pmid: 12169504].
289 Honest H, Bachmann LM, Knox EM, et al. The accuracy of various tests for bacterial vaginosis in predicting preterm birth: a systematic review. BJOG. 2004;111(5):409-22. [pmid: 15104603].
290 Honest H, Bachmann LM, Ngai C, et al. The accuracy of maternal anthropometry measurements as predictor for spontaneous preterm birth—a systematic review. Eur J Obstet Gynecol Reprod Biol. 2005;119(1):11-20. [pmid: 15734079].
291 Honest H, Bachmann LM, Sengupta R, et al. Accuracy of absence of fetal breathing movements in predicting preterm birth: a systematic review. Ultrasound Obstet Gynecol. 2004;24(1):94-100. [pmid: 15229924].
292 Honest H, Sharma S, Khan KS. Rapid tests for group B Streptococcus colonization in laboring women: a systematic review. Pediatrics. 2006;117(4):1055-66. [pmid: 16585299].
293 Hoogendam A, Buntinx F, de Vet HC. The diagnostic value of digital rectal examination in primary care screening for prostate cancer: a meta-analysis. Fam Pract. 1999;16(6):621-6. [pmid: 10625141].
294 Horsthuis K, Bipat S, Bennink RJ, et al. Inflammatory bowel disease diagnosed with US, MR, scintigraphy, and CT: meta-analysis of prospective studies. Radiology. 2008;247(1):64-79. [pmid: 18372465].
295 Horsthuis K, Bipat S, Stokkers PC, et al. Magnetic resonance imaging for evaluation of disease activity in Crohn's disease: a systematic review. Eur Radiol. 2009;19(6):1450-60. [pmid: 19189109].
296 Houssami N, Ciatto S, Macaskill P, et al. Accuracy and surgical impact of magnetic resonance imaging in breast cancer staging: systematic review and meta-analysis in detection of multifocal and multicentric cancer. J Clin Oncol. 2008;26(19):3248-58. [pmid: 18474876].
297 Hovels AM, Heesakkers RA, Adang EM, et al. The diagnostic accuracy of CT and MRI in the staging of pelvic lymph nodes in patients with prostate cancer: a meta-analysis. Clin Radiol. 2008;63(4):387-95. [pmid: 18325358].
298 Hrung JM, Sonnad SS, Schwartz JS, et al. Accuracy of MR imaging in the work-up of suspicious breast lesions: a diagnostic meta-analysis. Acad Radiol. 1999;6(7):387-97. [pmid: 10410164].
299 Huang SH, Hwang D, Lockwood G, et al. Predictive value of tumor thickness for cervical lymph-node involvement in squamous cell carcinoma of the oral cavity: a meta-analysis of reported studies. Cancer. 2009;115(7):1489-97. [pmid: 19197973].
300 Huebner RH, Park KC, Shepherd JE, et al. A meta-analysis of the literature for whole-body FDG PET detection of recurrent colorectal cancer. J Nucl Med. 2000;41(7):1177-89. [pmid: 10914907].
301 Huicho L, Campos M, Rivera J, et al. Fecal screening tests in the approach to acute infectious diarrhea: a scientific overview. Pediatr Infect Dis J. 1996;15(6):486-94. [pmid: 8783344].
302 Huicho L, Campos-Sanchez M, Alamo C. Metaanalysis of urine screening tests for determining the risk of urinary tract infection in children. Pediatr Infect Dis J. 2002;21(1):1-11. 88. [pmid: 11791090].
303 Hurlbut TA 3rd, Littenberg B. The diagnostic accuracy of rapid dipstick tests to predict urinary tract infection. Am J Clin Pathol. 1991;96(5):582-8. [pmid: 1951183].
304 Hurley JC. Concordance of endotoxemia with gram-negative bacteremia. A meta-analysis using receiver operating characteristic curves. Arch Pathol Lab Med. 2000;124(8):1157-64. [pmid: 10923076].
305 Hussain R, Buscombe JR. A meta-analysis of scintimammography: an evidence-based approach to its clinical utility. Nucl Med Commun. 2006;27(7):589-94. [pmid: 16794520].
306 Ie YL, Verdonschot EH. Performance of diagnostic systems in occlusal caries detection compared. Community Dent Oral Epidemiol. 1994;22(3):187-91. [pmid: 8070247].
307 Imran MB, Khan MA, Aslam MN, et al. Diagnosis of coronary artery disease by stress echocardiography and perfusion scintigraphy. J Coll Physicians Surg Pak. 2003;13(8):465-70. [pmid: 12921688].
308 Inaba Y, Bergmann SR. Diagnostic accuracy of beta-methyl-p-[123I]-iodophenyl-pentadecanoic acid (BMIPP) imaging: a meta-analysis. J Nucl Cardiol. 2008;15(3):345-52. [pmid: 18513641].
309 Ioannidis JP, Salem D, Chew PW, et al. Accuracy of imaging technologies in the diagnosis of acute cardiac ischemia in the emergency department: a meta-analysis. Ann Emerg Med. 2001;37(5):471-7. [pmid: 11326183].
310 Ioannidis JP, Salem D, Chew PW, et al. Accuracy and clinical effect of out-of-hospital electrocardiography in the diagnosis of acute cardiac ischemia: a meta-analysis. Ann Emerg Med. 2001;37(5):461-70. [pmid: 11326182].
311 Isasi CR, Lu P, Blaufox MD. A metaanalysis of 18F-2-deoxy-2-fluoro-D-glucose positron emission tomography in the staging and restaging of patients with lymphoma. Cancer. 2005;104(5):1066-74. [pmid: 16047335].
312 Isasi CR, Moadel RM, Blaufox MD. A meta-analysis of FDG-PET for the evaluation of breast cancer recurrence and metastases. Breast Cancer Res Treat. 2005;90(2):105-12. [pmid: 15803356].
313 Isles MG, McConkey C, Mehanna HM. A systematic review and meta-analysis of the role of positron emission tomography in the follow up of head and neck squamous cell carcinoma following radiotherapy or chemoradiotherapy. Clin Otolaryngol. 2008;33(3):210-22. [pmid: 18559026].
314 Jahromi AS, Cina CS, Liu Y, et al. Sensitivity and specificity of color duplex ultrasound measurement in the estimation of internal carotid artery stenosis: a systematic review and meta-analysis. J Vasc Surg. 2005;41(6):962-72. [pmid: 15944595].
315 Jain T, Soules MR, Collins JA. Comparison of basal follicle-stimulating hormone versus the clomiphene citrate challenge test for ovarian reserve screening. Fertil Steril. 2004;82(1):180-5. [pmid: 15237009].
316 James A, Matchar DB, Myers ER. Testing for von Willebrand disease in women with menorrhagia: a systematic review. Obstet Gynecol. 2004;104(2):381-8. [pmid: 15292016].
317 Janne d'Othee B, Siebert U, Cury R, et al. A systematic review on diagnostic accuracy of CT-based detection of significant coronary artery disease. Eur J Radiol. 2008;65(3):449-61. [pmid: 17590554].
318 Jellema P, van der Windt DA, Schellevis FG, et al. Systematic review: accuracy of symptom-based criteria for diagnosis of irritable bowel syndrome in primary care. Aliment Pharmacol Ther. 2009;30(7):695-706. [pmid: 19575763].
319 Jensen JE, Nielsen SH, Foged L, et al. The MICRAL test for diabetic microalbuminuria: predictive values as a function of prevalence. Scand J Clin Lab Invest. 1996;56(2):117-22. [pmid: 8743103].
320 Jiang J, Shi HZ, Liang QL, et al. Diagnostic value of interferon-gamma in tuberculous pleurisy: a metaanalysis. Chest. 2007;131(4):1133-41. [pmid: 17426220].
321 Jimenez D, Uresandi F, Otero R, et al. Troponin-based risk stratification of patients with acute nonmassive pulmonary embolism: systematic review and metaanalysis. Chest. 2009;136(4):974-82. [pmid: 19465511].
322 Jing JY, Huang TC, Cui W, et al. Should FEV1/FEV6 replace FEV1/FVC ratio to detect airway obstruction? A metaanalysis. Chest. 2009;135(4):991-8. [pmid: 19349398].
323 Jiyong J, Tiancha H, Wei C, et al. Diagnostic value of the soluble triggering receptor expressed on myeloid cells-1 in bacterial infection: a meta-analysis. Intensive Care Med. 2009;35(4):587-95. [pmid: 18936908].
324 Jones AE, Fiechtl JF, Brown MD, et al. Procalcitonin test in the diagnosis of bacteremia: a meta-analysis. Ann Emerg Med. 2007;50(1):34-41. [pmid: 17161501].
325 Jones CM, Athanasiou T. Is virtual bronchoscopy an efficient diagnostic tool for the thoracic surgeon?. Ann Thorac Surg. 2005;79(1):365-74. [pmid: 15620990].
326 Jones CM, Athanasiou T, Dunne N, et al. Multi-detector computed tomography in coronary artery bypass graft assessment: a meta-analysis. Ann Thorac Surg. 2007;83(1):341-8. [pmid: 17184705].
327 Jones CM, Athanasiou T, Nair S, et al. Do technical parameters affect the diagnostic accuracy of virtual bronchoscopy in patients with suspected airways stenosis?. Eur J Radiol. 2005;55(3):445-51. [pmid: 16129255].
328 Jones CM, Athanasiou T, Tekkis PP, et al. Does Doppler echography have a diagnostic role in patency assessment of internal thoracic artery grafts?. Eur J Cardiothorac Surg. 2005;28(5):692-700. [pmid: 16194605].
329 Jorgensen K, Andersen TJ, Dam H. The diagnostic efficiency of the Rorschach Depression Index and the Schizophrenia Index: a review. Assessment. 2000;7(3):259-80. [pmid: 11037393].
330 Jorm AF. Methods of screening for dementia: a meta-analysis of studies comparing an informant questionnaire with a brief cognitive test. Alzheimer Dis Assoc Disord. 1997;11(3):158-62. [pmid: 9305501].
331 Joshi U, Raijmakers PG, Riphagen II, et al. Attenuation-corrected vs. nonattenuation-corrected 2-deoxy-2-[F-18]fluoro-D-glucose-positron emission tomography in oncology: a systematic review. Mol Imaging Biol. 2007;9(3):99-105. [pmid: 17318671].
332 Kalantri S, Pai M, Pascopella L, et al. Bacteriophage- based tests for the detection of Mycobacterium tuberculosis in clinical specimens: a systematic review and meta-analysis. BMC Infect Dis. 2005;5:59. [pmid: 16022735].
333 Kallmes DF, Omary RA, Dix JE, et al. Specificity of MR angiography as a confirmatory test of carotid artery stenosis. AJNR Am J Neuroradiol. 1996;17(8):1501-6. [pmid: 8883649].
334 Kapoor A, Page S, Lavalley M, et al. Magnetic resonance imaging for diagnosing foot osteomyelitis: a meta-analysis. Arch Intern Med. 2007;167(2):125-32. [pmid: 17242312].
335 Karassa FB, Matsagas MI, Schmidt WA, et al. Meta-analysis: test performance of ultrasonography for giant-cell arteritis. Ann Intern Med. 2005;142(5):359-69. [pmid: 15738455].
336 Kardaun JW, Kardaun OJ. Comparative diagnostic performance of three radiological procedures for the detection of lumbar disk herniation. Methods Inf Med. 1990;29(1):12-22. [pmid: 2308524].
337 Karger R, Donner-Banzhoff N, Muller HH, et al. Diagnostic performance of the platelet function analyzer (PFA-100) for the detection of disorders of primary haemostasis in patients with a bleeding history-a systematic review and meta-analysis. Platelets. 2007;18(4):249-60. [pmid: 17538845].
338 Kassai B, Boissel JP, Cucherat M, et al. A systematic review of the accuracy of ultrasound in the diagnosis of deep venous thrombosis in asymptomatic patients. Thromb Haemost. 2004;91(4):655-66. [pmid: 15045125].
339 Kearon C, Julian JA, Newman TE, et al. Noninvasive diagnosis of deep venous thrombosis. McMaster Diagnostic Imaging Practice Guidelines Initiative. Ann Intern Med. 1998;128(8):663-77. [pmid: 9537941].
340 Kellen M, Aronson S, Roizen MF, et al. Predictive and diagnostic tests of renal failure: a review. Anesth Analg. 1994;78(1):134-42. [pmid: 8267149].
341 Kelly S, Harris KM, Berry E, et al. A systematic review of the staging performance of endoscopic ultrasound in gastro-oesophageal carcinoma. Gut. 2001;49(4):534-9. [pmid: 11559651].
342 Kertai MD, Boersma E, Bax JJ, et al. A meta-analysis comparing the prognostic accuracy of six diagnostic tests for predicting perioperative cardiac risk in patients undergoing major vascular surgery. Heart. 2003;89(11):1327-34. [pmid: 14594892].
343 Khan S, Cloud GC, Kerry S, et al. Imaging of vertebral artery stenosis: a systematic review. J Neurol Neurosurg Psychiatry. 2007;78(11):1218-25. [pmid: 17287234].
344 Khunti K, Squire I, Abrams KR, et al. Accuracy of a 12-lead electrocardiogram in screening patients with suspected heart failure for open access echocardiography: a systematic review and meta-analysis. Eur J Heart Fail. 2004;6(5):571-6. [pmid: 15352303].
345 Kievit W, de Bruin JH, Adang EM, et al. Current clinical selection strategies for identification of hereditary non-polyposis colorectal cancer families are inadequate: a meta-analysis. Clin Genet. 2004;65(4):308-16. [pmid: 15025724].
346 Kim C, Kwok YS, Heagerty P, et al. Pharmacologic stress testing for coronary disease diagnosis: A meta-analysis. Am Heart J. 2001;142(6):934-44. [pmid: 11717594].
347 Kinkel K, Hricak H, Lu Y, et al. US characterization of ovarian masses: a meta-analysis. Radiology. 2000;217(3):803-11. [pmid: 11110947].
348 Kinkel K, Kaji Y, Yu KK, et al. Radiologic staging in patients with endometrial cancer: a meta-analysis. Radiology. 1999;212(3):711-8. [pmid: 10478237].
349 Kittler H, Pehamberger H, Wolff K, et al. Diagnostic accuracy of dermoscopy. Lancet Oncol. 2002;3(3):159-65. [pmid: 11902502].
350 Klassen TP, Rowe PC. Selecting diagnostic tests to identify febrile infants less than 3 months of age as being at low risk for serious bacterial infection: a scientific overview. J Pediatr. 1992;121(5 Pt 1):671-6. [pmid: 1432412].
351 Klompas M. Does this patient have an acute thoracic aortic dissection?. JAMA. 2002;287(17):2262-72. [pmid: 11980527].
352 Koch H, Meerkerk GJ, Zaat JO, et al. Accuracy of carbohydrate-deficient transferrin in the detection of excessive alcohol consumption: a systematic review. Alcohol Alcohol. 2004;39(2):75-85. [pmid: 14998820].
353 Koelemay MJ, den Hartog D, Prins MH, et al. Diagnosis of arterial disease of the lower extremities with duplex ultrasonography. Br J Surg. 1996;83(3):404-9. [pmid: 8665208].
354 Koelemay MJ, Lijmer JG, Stoker J, et al. Magnetic resonance angiography for the evaluation of lower extremity arterial disease: a meta-analysis. JAMA. 2001;285(10):1338-45. [pmid: 11255390].
355 Koelemay MJ, Nederkoorn PJ, Reitsma JB, et al. Systematic review of computed tomographic angiography for assessment of carotid artery disease. Stroke. 2004;35(10):2306-12. [pmid: 15345798].
356 Koliopoulos G, Arbyn M, Martin-Hirsch P, et al. Diagnostic accuracy of human papillomavirus testing in primary cervical screening: a systematic review and meta-analysis of non-randomized studies. Gynecol Oncol. 2007;104(1):232-46. [pmid: 17084886].
357 Koopmans CM, van Pampus MG, Groen H, et al. Accuracy of serum uric acid as a predictive test for maternal complications in pre-eclampsia: bivariate meta-analysis and decision analysis. Eur J Obstet Gynecol Reprod Biol. 2009;146(1):8-14. [pmid: 19540647].
358 Koumans EH, Johnson RE, Knapp JS, et al. Laboratory testing for Neisseria gonorrhoeae by recently introduced nonculture tests: a performance review with clinical and public health considerations. Clin Infect Dis. 1998;27(5):1171-80. [pmid: 9827265].
359 Kowalski J, Tu XM, Jia G, et al. A comparative meta-analysis on the variability in test performance among FDA-licensed enzyme immunosorbent assays for HIV antibody testing. J Clin Epidemiol. 2001;54(5):448-61. [pmid: 11337207].
360 Kraag N, Thijs C, Knipschild P. Dyspepsia—how noisy are gallstones? A meta-analysis of epidemiologic studies of biliary pain, dyspeptic symptoms, and food intolerance. Scand J Gastroenterol. 1995;30(5):411-21. [pmid: 7638565].
361 Krug B, Crott R, Lonneux M, et al. Role of PET in the initial staging of cutaneous malignant melanoma: systematic review. Radiology. 2008;249(3):836-44. [pmid: 19011184].
362 Kumar Y, Gurusamy K, Pamecha V, et al. Tumor M2-pyruvate kinase as tumor marker in exocrine pancreatic cancer a meta-analysis. Pancreas. 2007;35(2):114-9. [pmid: 17632316].
363 Kumbhani DJ, Ingelmo CP, Schoenhagen P, et al. Meta-analysis of diagnostic efficacy of 64-slice computed tomography in the evaluation of coronary in-stent restenosis. Am J Cardiol. 2009;103(12):1675-81. [pmid: 19539075].
364 Kwee TC, Kwee RM. MR angiography in the follow-up of intracranial aneurysms treated with Guglielmi detachable coils: systematic review and meta-analysis. Neuroradiology. 2007;49(9):703-13. [pmid: 17646977].
365 Kwee TC, Kwee RM. Combined FDG-PET/CT for the detection of unknown primary tumors: systematic review and meta-analysis. Eur Radiol. 2009;19(3):731-44. [pmid: 18925401].
366 Kwee TC, Kwee RM, Alavi A. FDG-PET for diagnosing prosthetic joint infection: systematic review and metaanalysis. Eur J Nucl Med Mol Imaging. 2008;35(11):2122-32. [pmid: 18704405].
367 Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;83(5):660-6. [pmid: 10080415].
368 Kyzas PA, Evangelou E, Denaxa-Kyza D, et al. 18F-fluorodeoxyglucose positron emission tomography to evaluate cervical node metastases in patients with head and neck squamous cell carcinoma: a meta-analysis. J Natl Cancer Inst. 2008;100(10):712-20. [pmid: 18477804].
369 Lacasse Y, Wong E, Guyatt GH, et al. Transthoracic needle aspiration biopsy for the diagnosis of localised pulmonary lesions: a meta-analysis. Thorax. 1999;54(10):884-93. [pmid: 10491450].
370 Lahaye MJ, Engelen SM, Nelemans PJ, et al. Imaging for predicting the risk factors—the circumferential resection margin and nodal disease—of local recurrence in rectal cancer: a meta-analysis. Semin Ultrasound CT MR. 2005;26(4):259-68. [pmid: 16152740].
371 Lameris W, van Randen A, Bipat S, et al. Graded compression ultrasonography and computed tomography in acute colonic diverticulitis: meta-analysis of test accuracy. Eur Radiol. 2008;18(11):2498-511. [pmid: 18523784].
372 Latour-Perez J, Coves-Orts FJ, Abad-Terrado C, et al. Accuracy of B-type natriuretic peptide levels in the diagnosis of left ventricular dysfunction and heart failure: a systematic review. Eur J Heart Fail. 2006;8(4):390-9. [pmid: 16305826].
373 Lau J, Ioannidis JP, Balk EM, et al. Diagnosing acute cardiac ischemia in the emergency department: a systematic review of the accuracy and clinical effect of current technologies. Ann Emerg Med. 2001;37(5):453-60. [pmid: 11326181].
374 Lawrence WF, Liang W, Mandelblatt JS, et al. Serendipity in diagnostic imaging: magnetic resonance imaging of the breast. J Natl Cancer Inst. 1998;90(23):1792-800. [pmid: 9839519].
375 Leal YA, Flores LL, Garcia-Cortes LB, et al. Antibody-based detection tests for the diagnosis of Helicobacter pylori infection in children: a meta-analysis. PLoS One. 2008;3(11):e3751. [pmid: 19015732].
376 Lederle FA, Simel DL. The rational clinical examination. Does this patient have abdominal aortic aneurysm?. JAMA. 1999;281(1):77-82. [pmid: 9892455].
377 Ledro-Cano D. Suspected choledocholithiasis: endoscopic ultrasound or magnetic resonance cholangio-pancreatography? A systematic review. Eur J Gastroenterol Hepatol. 2007;19(11):1007-11. [pmid: 18049172].
378 Lee A, Fan LT, Gin T, et al. A systematic review (meta-analysis) of the accuracy of the Mallampati tests to predict the difficult airway. Anesth Analg. 2006;102(6):1867-78. [pmid: 16717341].
379 Lee JB, Ahmad S, Gale CP. Detection of coins ingested by children using a handheld metal detector: a systematic review. Emerg Med J. 2005;22(12):839-44. [pmid: 16299189].
380 Lee R, Localio AR, Armstrong K, et al. A meta-analysis of the performance characteristics of the free prostate-specific antigen test. Urology. 2006;67(4):762-8. [pmid: 16600352].
381 Leitich H, Kaider A. Fetal fibronectin—how useful is it in the prediction of preterm birth?. BJOG. Suppl 20. 2003;110:66-70. [pmid: 12763115].
382 Lensing AW, Hirsh J. 125I-fibrinogen leg scanning: reassessment of its role for the diagnosis of venous thrombosis in post-operative patients. Thromb Haemost. 1993;69(1):2-7. [pmid: 8446932].
383 LeSar CJ, Meier GH, DeMasi RJ, et al. The utility of color duplex ultrasonography in the diagnosis of temporal arteritis. J Vasc Surg. 2002;36(6):1154-60. [pmid: 12469046].
384 Lewis NR, Scott BB. Systematic review: the use of serology to exclude or diagnose coeliac disease (a comparison of the endomysial and tissue transglutaminase antibody tests). Aliment Pharmacol Ther. 2006;24(1):47-54. [pmid: 16803602].
385 Li J. Capnography alone is imperfect for endotracheal tube placement confirmation during emergency intubation. J Emerg Med. 2001;20(3):223-9. [pmid: 11267809].
386 Liang QL, Shi HZ, Qin XJ, et al. Diagnostic accuracy of tumour markers for malignant pleural effusion: a meta-analysis. Thorax. 2008;63(1):35-41. [pmid: 17573438].
387 Liang QL, Shi HZ, Wang K, et al. Diagnostic accuracy of adenosine deaminase in tuberculous pleurisy: a meta-analysis. Respir Med. 2008;102(5):744-54. [pmid: 18222681].
388 Liberman M, Sampalis F, Mulder DS, et al. Breast cancer diagnosis by scintimammography: a meta-analysis and review of the literature. Breast Cancer Res Treat. 2003;80(1):115-26. [pmid: 12889605].
389 Liedberg J, Panmekiate S, Petersson A, et al. Evidence-based evaluation of three imaging methods for the temporomandibular disc. Dentomaxillofac Radiol. 1996;25(5):234-41. [pmid: 9161176].
390 Ling DI, Flores LL, Riley LW, et al. Commercial nucleic-acid amplification tests for diagnosis of pulmonary tuberculosis in respiratory specimens: meta-analysis and meta-regression. PLoS One. 2008;3(2):e1536. [pmid: 18253484].
391 Ling DI, Zwerling AA, Pai M. GenoType MTBDR assays for the diagnosis of multidrug-resistant tuberculosis: a meta-analysis. Eur Respir J. 2008;32(5):1165-74. [pmid: 18614561].
392 Littenberg B, Mushlin AI. Technetium bone scanning in the diagnosis of osteomyelitis: a meta-analysis of test performance. Diagnostic Technology Assessment Consortium. J Gen Intern Med. 1992;7(2):158-64. [pmid: 1487763].
393 Liu J, Xu Y, Wang J. Ultrasonography, computed tomography and magnetic resonance imaging for diagnosis of ovarian carcinoma. Eur J Radiol. 2007;62(3):328-34. [pmid: 17433597].
394 Liu T, Xu W, Yan WL, et al. FDG-PET, CT, MRI for diagnosis of local residual or recurrent nasopharyngeal carcinoma, which one is the best? A systematic review. Radiother Oncol. 2007;85(3):327-35. [pmid: 18037523].
395 Locker T, Goodacre S, Sampson F, et al. Meta-analysis of plethysmography and rheography in the diagnosis of deep vein thrombosis. Emerg Med J. 2006;23(8):630-5. [pmid: 16858098].
396 Lord SJ, Lei W, Craft P, et al. A systematic review of the effectiveness of magnetic resonance imaging (MRI) as an addition to mammography and ultrasound in screening young women at high risk of breast cancer. Eur J Cancer. 2007;43(13):1905-17. [pmid: 17681781].
397 Lotan Y, Roehrborn CG. Sensitivity and specificity of commonly available bladder tumor markers versus cytology: results of a comprehensive literature review and meta-analyses. Urology. 2003;61(1):109-18. discussion 18. [pmid: 12559279].
398 Loy CT, Irwig LM, Katelaris PH, et al. Do commercial serological kits for Helicobacter pylori infection differ in accuracy? A meta-analysis. Am J Gastroenterol. 1996;91(6):1138-44. [pmid: 8651160].
399 Lyman GH, Kuderer NM. Gene expression profile assays as predictors of recurrence-free survival in early-stage breast cancer: a metaanalysis. Clin Breast Cancer. 2006;7(5):372-9. [pmid: 17239261].
400 Lysakowski C, Walder B, Costanza MC, et al. Transcranial Doppler versus angiography in patients with vasospasm due to a ruptured cerebral aneurysm: A systematic review. Stroke. 2001;32(10):2292-8. [pmid: 11588316].
401 Maas JW, Evers JL, ter Riet G, et al. Pregnancy rate following normal versus abnormal hysterosalpingography findings: a meta-analysis. Gynecol Obstet Invest. 1997;43(2):79-83. [pmid: 9067711].
402 MacDermid JC, Wessel J. Clinical diagnosis of carpal tunnel syndrome: a systematic review. J Hand Ther. 2004;17(2):309-19. [pmid: 15162113].
403 Mackenzie R, Palmer CR, Lomas DJ, et al. Magnetic resonance imaging of the knee: diagnostic performance studies. Clin Radiol. 1996;51(4):251-7. [pmid: 8617036].
404 Madhok V, Falk G, Rogers A, et al. The accuracy of symptoms, signs and diagnostic tests in the diagnosis of left ventricular dysfunction in primary care: a diagnostic accuracy systematic review. BMC Fam Pract. 2008;9:56. [pmid: 18842141].
405 Maenza RL, Seaberg D, D'Amico F. A meta-analysis of blunt cardiac trauma: ending myocardial confusion. Am J Emerg Med. 1996;14(3):237-41. [pmid: 8639191].
406 Maguire S, Pickerd N, Farewell D, et al. Which clinical features distinguish inflicted from non-inflicted brain injury? A systematic review. Arch Dis Child. 2009;94(11):860-7. [pmid: 19531526].
407 Maheshwari A, Gibreel A, Bhattacharya S, et al. Dynamic tests of ovarian reserve: a systematic review of diagnostic accuracy. Reprod Biomed Online. 2009;18(5):717-34. [pmid: 19549453].
408 Makrydimas G, Sotiriadis A, Ioannidis JP. Screening performance of first-trimester nuchal translucency for major cardiac defects: a meta-analysis. Am J Obstet Gynecol. 2003;189(5):1330-5. [pmid: 14634564].
409 Mallo RD, Salem L, Lalani T, et al. Computed tomography diagnosis of ischemia and complete obstruction in small bowel obstruction: a systematic review. J Gastrointest Surg. 2005;9(5):690-4. [pmid: 15862265].
410 Mann JJ, Currier D, Stanley B, et al. Can biological tests assist prediction of suicide in mood disorders?. Int J Neuropsychopharmacol. 2006;9(4):465-74. [pmid: 15967058].
411 Mann RM, Hoogeveen YL, Blickman JG, et al. MRI compared to conventional diagnostic work-up in the detection and evaluation of invasive lobular carcinoma of the breast: a review of existing literature. Breast Cancer Res Treat. 2008;107(1):1-14. [pmid: 18043894].
412 Mantha S, Roizen MF, Barnard J, et al. Relative effectiveness of four preoperative tests for predicting adverse cardiac outcomes after vascular surgery: a meta-analysis. Anesth Analg. 1994;79(3):422-33. [pmid: 8067544].
413 Marik PE, Baram M, Vahid B. Does central venous pressure predict fluid responsiveness? A systematic review of the literature and the tale of seven mares. Chest. 2008;134(1):172-8. [pmid: 18628220].
414 Marik PE, Cavallazzi R, Vasu T, et al. Dynamic changes in arterial waveform derived variables and fluid responsiveness in mechanically ventilated patients: a systematic review of the literature. Crit Care Med. 2009;37(9):2642-7. [pmid: 19602972].
415 Marill KA. Serum D-dimer is a sensitive test for the detection of acute aortic dissection: a pooled meta-analysis. J Emerg Med. 2008;34(4):367-76. [pmid: 18207693].
416 Markert RJ, Walley ME, Guttman TG, et al. A pooled analysis of the Ottawa ankle rules used on adults in the ED. Am J Emerg Med. 1998;16(6):564-7. [pmid: 9786538].
417 Marmo R, Rotondano G, Piscopo R, et al. Meta-analysis: capsule enteroscopy vs. conventional modalities in diagnosis of small bowel diseases. Aliment Pharmacol Ther. 2005;22(7):595-604. [pmid: 16181299].
418 Martin A, Panaiotov S, Portaels F, et al. The nitrate reductase assay for the rapid detection of isoniazid and rifampicin resistance in Mycobacterium tuberculosis: a systematic review and meta-analysis. J Antimicrob Chemother. 2008;62(1):56-64. [pmid: 18407918].
419 Martin A, Portaels F, Palomino JC. Colorimetric redox-indicator methods for the rapid detection of multidrug resistance in Mycobacterium tuberculosis: a systematic review and meta-analysis. J Antimicrob Chemother. 2007;59(2):175-83. [pmid: 17135182].
420 Martin JL, Williams KS, Sutton AJ, et al. Systematic review and meta-analysis of methods of diagnostic assessment for urinary incontinence. Neurourol Urodyn. 2006;25(7):674-83. discussion 84. [pmid: 17016795].
421 Marx A, Pewsner D, Egger M, et al. Meta-analysis: accuracy of rapid tests for malaria in travelers returning from endemic areas. Ann Intern Med. 2005;142(10):836-46. [pmid: 15897534].
422 Mase SR, Ramsay A, Ng V, et al. Yield of serial sputum specimen examinations in the diagnosis of pulmonary tuberculosis: a systematic review. Int J Tuberc Lung Dis. 2007;11(5):485-95. [pmid: 17439669].
423 McGee S, Abernethy WB 3rd, Simel DL. The rational clinical examination. Is this patient hypovolemic?. JAMA. 1999;281(11):1022-9. [pmid: 10086438].
424 Medeiros LR, Rosa DD, da Rosa MI, et al. Accuracy of ultrasonography with color Doppler in ovarian tumor: a systematic quantitative review. Int J Gynecol Cancer. 2009;19(7):1214-20. [pmid: 19823057].
425 Medeiros LR, Rosa DD, da Rosa MI, et al. Accuracy of CA 125 in the diagnosis of ovarian tumors: a quantitative systematic review. Eur J Obstet Gynecol Reprod Biol. 2009;142(2):99-105. [pmid: 18995946].
426 Medeiros LR, Rosa DD, Edelweiss MI, et al. Accuracy of frozen-section analysis in the diagnosis of ovarian tumors: a systematic quantitative review. Int J Gynecol Cancer. 2005;15(2):192-202. [pmid: 15823099].
427 Meijer AB, O YL, Geleijns J, et al. Meta-analysis of 40- and 64-MDCT angiography for assessing coronary artery stenosis. AJR Am J Roentgenol. 2008;191(6):1667-75. [pmid: 19020234].
428 Menke J. Diagnostic accuracy of contrast-enhanced MR angiography in severe carotid stenosis: meta-analysis with metaregression of different techniques. Eur Radiol. 2009;19(9):2204-16. [pmid: 19399505].
429 Menzies D, Pai M, Comstock G. Meta-analysis: new tests for the diagnosis of latent tuberculosis infection: areas of uncertainty and recommendations for research. Ann Intern Med. 2007;146(5):340-54. [pmid: 17339619].
430 Meredith SM, Sanchez-Ramos L, Kaunitz AM. Diagnostic accuracy of transvaginal sonography for the diagnosis of adenomyosis: systematic review and metaanalysis. Am J Obstet Gynecol. 2009;201(1):107 e1-6. [pmid: 19398089].
431 Merritt RM, Williams MF, James TH, et al. Detection of cervical metastasis. A meta-analysis comparing computed tomography with physical examination. Arch Otolaryngol Head Neck Surg. 1997;123(2):149-52. [pmid: 9046281].
432 Meserve BB, Cleland JA, Boucher TR. A meta-analysis examining clinical test utilities for assessing meniscal injury. Clin Rehabil. 2008;22(2):143-61. [pmid: 18212035].
433 Meserve BB, Cleland JA, Boucher TR. A meta-analysis examining clinical test utility for assessing superior labral anterior posterior lesions. Am J Sports Med. 2009;37(11):2252-8. [pmid: 19095895].
434 Met R, Bipat S, Legemate DA, et al. Diagnostic performance of computed tomography angiography in peripheral arterial disease: a systematic review and meta-analysis. JAMA. 2009;301(4):415-24. [pmid: 19176443].
435 Metz LD, Beattie M, Hom R, et al. The prognostic value of normal exercise myocardial perfusion imaging and exercise echocardiography: a meta-analysis. J Am Coll Cardiol. 2007;49(2):227-37. [pmid: 17222734].
436 Micames CG, McCrory DC, Pavey DA, et al. Endoscopic ultrasound-guided fine-needle aspiration for non-small cell lung cancer staging: A systematic review and metaanalysis. Chest. 2007;131(2):539-48. [pmid: 17296659].
437 Mijnhout GS, Hoekstra OS, van Tulder MW, et al. Systematic review of the diagnostic accuracy of (18)F-fluorodeoxyglucose positron emission tomography in melanoma patients. Cancer. 2001;91(8):1530-42. [pmid: 11301402].
438 Miltenburg DM, Nuchtern JG, Jaksic T, et al. Laparoscopic evaluation of the pediatric inguinal hernia—a meta-analysis. J Pediatr Surg. 1998;33(6):874-9. [pmid: 9660219].
439 Mirvis SE, Shanmuganathan K, Miller BH, et al. Traumatic aortic injury: diagnosis with contrast-enhanced thoracic CT—five-year experience at a major trauma center. Radiology. 1996;200(2):413-22. [pmid: 8685335].
440 Mistry K, Cable G. Meta-analysis of prostate-specific antigen and digital rectal examination as screening tests for prostate carcinoma. J Am Board Fam Pract. 2003;16(2):95-101. [pmid: 12665174].
441 Mitchell AJ. Are one or two simple questions sufficient to detect depression in cancer and palliative care? A Bayesian meta-analysis. Br J Cancer. 2008;98(12):1934-43. [pmid: 18506146].
442 Mitchell AJ. The clinical significance of subjective memory complaints in the diagnosis of mild cognitive impairment and dementia: a meta-analysis. Int J Geriatr Psychiatry. 2008;23(11):1191-202. [pmid: 18500688].
443 Mitchell AJ. CSF phosphorylated tau in the diagnosis and prognosis of mild cognitive impairment and Alzheimer's disease: a meta-analysis of 51 studies. J Neurol Neurosurg Psychiatry. 2009;80(9):966-75. [pmid: 19465413].
444 Mitchell AJ. A meta-analysis of the accuracy of the mini-mental state examination in the detection of dementia and mild cognitive impairment. J Psychiatr Res. 2009;43(4):411-31. [pmid: 18579155].
445 Mitchell AJ, Coyne JC. Do ultra-short screening instruments accurately detect depression in primary care? A pooled analysis and meta-analysis of 22 studies. Br J Gen Pract. 2007;57(535):144-51. [pmid: 17263931].
446 Mitchell AJ, Vaze A, Rao S. Clinical diagnosis of depression in primary care: a meta-analysis. Lancet. 2009;374(9690):609-19. [pmid: 19640579].
447 Mitchell AM, Brown MD, Menown IB, et al. Novel protein markers of acute coronary syndrome complications in low-risk outpatients: a systematic review of potential use in the emergency department. Clin Chem. 2005;51(11):2005-12. [pmid: 16166170].
448 Mitchell MF, Cantor SB, Ramanujam N, et al. Fluorescence spectroscopy for diagnosis of squamous intraepithelial lesions of the cervix. Obstet Gynecol. 1999;93(3):462-70. [pmid: 10075001].
449 Mitchell MF, Schottenfeld D, Tortolero-Luna G, et al. Colposcopy for the diagnosis of squamous intraepithelial lesions: a meta-analysis. Obstet Gynecol. 1998;91(4):626-31. [pmid: 9540955].
450 Mofidi R, Suttie SA, Patil PV, et al. The value of procalcitonin at predicting the severity of acute pancreatitis and development of infected pancreatic necrosis: systematic review. Surgery. 2009;146(1):72-81. [pmid: 19541012].
451 Mol BW, Bayram N, Lijmer JG, et al. The performance of CA-125 measurement in the detection of endometriosis: a meta-analysis. Fertil Steril. 1998;70(6):1101-8. [pmid: 9848302].
452 Mol BW, Dijkman B, Wertheim P, et al. The accuracy of serum chlamydial antibodies in the diagnosis of tubal pathology: a meta-analysis. Fertil Steril. 1997;67(6):1031-7. [pmid: 9176440].
453 Mol BW, Lijmer JG, Ankum WM, et al. The accuracy of single serum progesterone measurement in the diagnosis of ectopic pregnancy: a meta-analysis. Hum Reprod. 1998;13(11):3220-7. [pmid: 9853884].
454 Mol BW, Meijer S, Yuppa S, et al. Sperm penetration assay in predicting successful in vitro fertilization. A meta-analysis. J Reprod Med. 1998;43(6):503-8. [pmid: 9653696].
455 Moles DR, Downer MC, Speight PM. Meta-analysis of measures of performance reported in oral cancer and precancer screening studies. Br Dent J. 2002;192(6):340-4. discussion 32. [pmid: 15552072].
456 Morgan M, Kalantri S, Flores L, et al. A commercial line probe assay for the rapid detection of rifampicin resistance in Mycobacterium tuberculosis: a systematic review and meta-analysis. BMC Infect Dis. 2005;5:62. [pmid: 16050959].
457 Morisson P, Neves DD. Evaluation of adenosine deaminase in the diagnosis of pleural tuberculosis: a Brazilian meta-analysis. J Bras Pneumol. 2008;34(4):217-24. [pmid: 18425258].
458 Moroney JT, Bagiella E, Desmond DW, et al. Meta-analysis of the Hachinski Ischemic Score in pathologically verified dementias. Neurology. 1997;49(4):1096-105. [pmid: 9339696].
459 Morris RK, Cnossen JS, Langejans M, et al. Serum screening with Down's syndrome markers to predict pre-eclampsia and small for gestational age: systematic review and meta-analysis. BMC Pregnancy Childbirth. 2008;8:33. [pmid: 18680570].
460 Morris RK, Malin GL, Khan KS, et al. Antenatal ultrasound to predict postnatal renal function in congenital lower urinary tract obstruction: systematic review of test accuracy. BJOG. 2009;116(10):1290-9. [pmid: 19438489].
461 Morris RK, Quinlan-Jones E, Kilby MD, et al. Systematic review of accuracy of fetal urine analysis to predict poor postnatal renal function in cases of congenital urinary tract obstruction. Prenat Diagn. 2007;27(10):900-11. [pmid: 17610312].
462 Morselli-Labate AM, Pezzilli R. Usefulness of serum IgG4 in the diagnosis and follow up of autoimmune pancreatitis: A systematic literature review and meta-analysis. J Gastroenterol Hepatol. 2009;24(1):15-36. [pmid: 19067780].
463 Mos IC, Klok FA, Kroft LJ, et al. Safety of ruling out acute pulmonary embolism by normal computed tomography pulmonary angiography in patients with an indication for computed tomography: systematic review and meta-analysis. J Thromb Haemost. 2009;7(9):1491-8. [pmid: 19552684].
464 Mowatt G, Burr JM, Cook JA, et al. Screening tests for detecting open-angle glaucoma: systematic review and meta-analysis. Invest Ophthalmol Vis Sci. 2008;49(12):5373-85. [pmid: 18614810].
465 Mowatt G, Cook JA, Hillis GS, et al. 64-Slice computed tomography angiography in the diagnosis and assessment of coronary artery disease: systematic review and meta-analysis. Heart. 2008;94(11):1386-93. [pmid: 18669550].
466 Muchow RD, Resnick DK, Abdel MP, et al. Magnetic resonance imaging (MRI) in the clearance of the cervical spine in blunt trauma: a meta-analysis. J Trauma. 2008;64(1):179-89. [pmid: 18188119].
467 Mulhall BP, Veerappan GR, Jackson JL. Meta-analysis: computed tomographic colonography. Ann Intern Med. 2005;142(8):635-50. [pmid: 15838071].
468 Munro W, Healy R. The validity and accuracy of clinical tests used to detect labral pathology of the shoulder—a systematic review. Man Ther. 2009;14(2):119-30. [pmid: 18996735].
469 Mushlin AI, Kouides RW, Shapiro DE. Estimating the accuracy of screening mammography: a meta-analysis. Am J Prev Med. 1998;14(2):143-53. [pmid: 9631167].
470 Nallamothu BK, Saint S, Bielak LF, et al. Electron-beam computed tomography in the diagnosis of coronary artery disease: a meta-analysis. Arch Intern Med. 2001;161(6):833-8. [pmid: 11268225].
471 Nandalur KR, Dwamena BA, Choudhri AF, et al. Diagnostic performance of stress cardiac magnetic resonance imaging in the detection of coronary artery disease: a meta-analysis. J Am Coll Cardiol. 2007;50(14):1343-53. [pmid: 17903634].
472 Nandalur KR, Dwamena BA, Choudhri AF, et al. Diagnostic performance of positron emission tomography in the detection of coronary artery disease: a meta-analysis. Acad Radiol. 2008;15(4):444-51. [pmid: 18342769].
473 Navare SM, Mather JF, Shaw LJ, et al. Comparison of risk stratification with pharmacologic and exercise stress myocardial perfusion imaging: a meta-analysis. J Nucl Cardiol. 2004;11(5):551-61. [pmid: 15472640].
474 Navarro JC, Lao AY, Sharma VK, et al. The accuracy of transcranial Doppler in the diagnosis of middle cerebral artery stenosis. Cerebrovasc Dis. 2007;23(5-6):325-30. [pmid: 17268162].
475 Nayak S, Olkin I, Liu H, et al. Meta-analysis: accuracy of quantitative ultrasound for identifying patients with osteoporosis. Ann Intern Med. 2006;144(11):832-41. [pmid: 16754925].
476 Nederkoorn PJ, van der Graaf Y, Hunink MG. Duplex ultrasound and magnetic resonance angiography compared with digital subtraction angiography in carotid artery stenosis: a systematic review. Stroke. 2003;34(5):1324-32. [pmid: 12690221].
477 Needham DM, Shufelt KA, Tomlinson G, et al. Troponin I and T levels in renal failure patients without acute coronary syndrome: a systematic review of the literature. Can J Cardiol. 2004;20(12):1212-8. [pmid: 15494773].
478 Nelemans PJ, Leiner T, de Vet HC, et al. Peripheral arterial disease: meta-analysis of the diagnostic performance of MR angiography. Radiology. 2000;217(1):105-14. [pmid: 11012430].
479 Ng PC, Dear PR. The predictive value of a normal ultrasound scan in the preterm baby—a meta-analysis. Acta Paediatr Scand. 1990;79(3):286-91. [pmid: 2139756].
480 Niemann T, Egelhof T, Bongartz G. Transthoracic sonography for the detection of pulmonary embolism—a meta-analysis. Ultraschall Med. 2009;30(2):150-6. [pmid: 19253205].
481 Niemann T, Kollmann T, Bongartz G. Diagnostic performance of low-dose CT for the detection of urolithiasis: a meta-analysis. AJR Am J Roentgenol. 2008;191(2):396-401. [pmid: 18647908].
482 Noble M, Bruening W, Uhl S, et al. Computer-aided detection mammography for breast cancer screening: systematic review and meta-analysis. Arch Gynecol Obstet. 2009;279(6):881-90. [pmid: 19023581].
483 Noguchi Y, Nagata-Kobayashi S, Stahl JE, et al. A meta-analytic comparison of echocardiographic stressors. Int J Cardiovasc Imaging. 2005;21(2-3):189-207. [pmid: 16015428].
484 Norlund A, Axelsson S, Dahlen G, et al. Economic aspects of the detection of occlusal dentine caries. Acta Odontol Scand. 2009;67(1):38-43. [pmid: 19031158].
485 Nourbakhsh A, Grady JJ, Garges KJ. Percutaneous spine biopsy: a meta-analysis. J Bone Joint Surg Am. 2008;90(8):1722-5. [pmid: 18676903].
486 Numans ME, Lau J, de Wit NJ, et al. Short-term treatment with proton-pump inhibitors as a test for gastroesophageal reflux disease: a meta-analysis of diagnostic test characteristics. Ann Intern Med. 2004;140(7):518-27. [pmid: 15068979].
487 Ochoa ME, Marin Mdel C, Frutos-Vivar F, et al. Cuff-leak test for the diagnosis of upper airway obstruction in adults: a systematic review and meta-analysis. Intensive Care Med. 2009;35(7):1171-9. [pmid: 19399474].
488 Oei EH, Nikken JJ, Verstijnen AC, et al. MR imaging of the menisci and cruciate ligaments: a systematic review. Radiology. 2003;226(3):837-48. [pmid: 12601211].
489 Oei SG, Helmerhorst FM, Keirse MJ. When is the post-coital test normal? A critical appraisal. Hum Reprod. 1995;10(7):1711-4. [pmid: 8582966].
490 Offringa M, Benbassat J. The value of urinary red cell shape in the diagnosis of glomerular and post-glomerular haematuria. A meta-analysis. Postgrad Med J. 1992;68(802):648-54. [pmid: 1448406].
491 Ogilvie GS, Patrick DM, Schulzer M, et al. Diagnostic accuracy of self collected vaginal specimens for human papillomavirus compared to clinician collected human papillomavirus specimens: a meta-analysis. Sex Transm Infect. 2005;81(3):207-12. [pmid: 15923286].
492 Ola B, Afnan M, Papaioannou S, et al. Accuracy of sperm-cervical mucus penetration tests in evaluating sperm motility in semen: a systematic quantitative review. Hum Reprod. 2003;18(5):1037-46. [pmid: 12721182].
493 Olaniyan OB. Validity of colposcopy in the diagnosis of early cervical neoplasia—a review. Afr J Reprod Health. 2002;6(3):59-69. [pmid: 12685410].
494 Olatidoye AG, Wu AH, Feng YJ, et al. Prognostic role of troponin T versus troponin I in unstable angina pectoris for cardiac events with meta-analysis comparing published studies. Am J Cardiol. 1998;81(12):1405-10. [pmid: 9645888].
495 Orlando LA, Kulasingam SL, Matchar DB. Meta-analysis: the detection of pancreatic malignancy with positron emission tomography. Aliment Pharmacol Ther. 2004;20(10):1063-70. [pmid: 15569108].
496 Orr RK, Porter D, Hartman D. Ultrasonography to evaluate adults for appendicitis: decision making based on meta-analysis and probabilistic reasoning. Acad Emerg Med. 1995;2(7):644-50. [pmid: 8521213].
497 Owens DK, Holodniy M, Garber AM, et al. Polymerase chain reaction for the diagnosis of HIV infection in adults. A meta-analysis with recommendations for clinical practice and study design. Ann Intern Med. 1996;124(9):803-15. [pmid: 8610949].
498 Owens DK, Holodniy M, McDonald TW, et al. A meta-analytic evaluation of the polymerase chain reaction for the diagnosis of HIV infection in infants. JAMA. 1996;275(17):1342-8. [pmid: 8614121].
499 Pai M, Flores LL, Hubbard A, et al. Nucleic acid amplification tests in the diagnosis of tuberculous pleuritis: a systematic review and meta-analysis. BMC Infect Dis. 2004;4:6. [pmid: 15102325].
500 Pai M, Flores LL, Pai N, et al. Diagnostic accuracy of nucleic acid amplification tests for tuberculous meningitis: a systematic review and meta-analysis. Lancet Infect Dis. 2003;3(10):633-43. [pmid: 14522262].
501 Pai M, Kalantri S, Pascopella L, et al. Bacteriophage-based assays for the rapid detection of rifampicin resistance in Mycobacterium tuberculosis: a meta-analysis. J Infect. 2005;51(3):175-87. [pmid: 16002146].
502 Pai M, Zwerling A, Menzies D. Systematic review: T-cell-based assays for the diagnosis of latent tuberculosis infection: an update. Ann Intern Med. 2008;149(3):177-84. [pmid: 18593687].
503 Pai NP, Tulsky JP, Cohan D, et al. Rapid point-of-care HIV testing in pregnant women: a systematic review and meta-analysis. Trop Med Int Health. 2007;12(2):162-73. [pmid: 17300622].
504 Pakos EE, Fotopoulos AD, Ioannidis JP. 18F-FDG PET for evaluation of bone marrow infiltration in staging of lymphoma: a meta-analysis. J Nucl Med. 2005;46(6):958-63. [pmid: 15937306].
505 Pakos EE, Ioannidis JP. The association of P-glycoprotein with response to chemotherapy and clinical outcome in patients with osteosarcoma. A meta-analysis. Cancer. 2003;98(3):581-9.
506 Pakos EE, Koumoulis HD, Fotopoulos AD, et al. Osteomyelitis: antigranulocyte scintigraphy with 99mTC radiolabeled monoclonal antibodies for diagnosis— meta-analysis. Radiology. 2007;245(3):732-41. [pmid: 17898328].
507 Pakos EE, Kyzas PA, Ioannidis JP. Prognostic significance of TP53 tumor suppressor gene expression and mutations in human osteosarcoma: a meta-analysis. Clin Cancer Res. 2004;10(18 Pt 1):6208-14. [pmid: 15448009].
508 Pakos EE, Trikalinos TA, Fotopoulos AD, et al. Prosthesis infection: diagnosis after total joint arthroplasty with antigranulocyte scintigraphy with 99mTc-labeled monoclonal antibodies—a meta-analysis. Radiology. 2007;242(1):101-8. [pmid: 17090716].
509 Paleri V, Rees G, Arullendran P, et al. Sentinel node biopsy in squamous cell cancer of the oral cavity and oral pharynx: a diagnostic meta-analysis. Head Neck. 2005;27(9):739-47. [pmid: 16047368].
510 Palomaki GE, Neveux LM, Haddow JE. Can reliable Down's syndrome detection rates be determined from prenatal screening intervention trials?. J Med Screen. 1996;3(1):12-7. [pmid: 8861045].
511 Parkes J, Guha IN, Roderick P, et al. Performance of serum marker panels for liver fibrosis in chronic hepatitis C. J Hepatol. 2006;44(3):462-74. [pmid: 16427156].
512 Patel SR, Wiese W, Patel SC, et al. Systematic review of diagnostic tests for vaginal trichomoniasis. Infect Dis Obstet Gynecol. 2000;8(5-6):248-57. [pmid: 11220487].
513 Patrick DL, Cheadle A, Thompson DC, et al. The validity of self-reported smoking: a review and meta-analysis. Am J Public Health. 1994;84(7):1086-93. [pmid: 8017530].
514 Patwardhan MB, McCrory DC, Matchar DB, et al. Alzheimer disease: operating characteristics of PET—a meta-analysis. Radiology. 2004;231(1):73-80. [pmid: 15068942].
515 Paulson WD, Ram SJ, Birk CG, et al. Does blood flow accurately predict thrombosis or failure of hemodialysis synthetic grafts? A meta-analysis. Am J Kidney Dis. 1999;34(3):478-85. [pmid: 10469858].
516 Peacock F, Morris DL, Anwaruddin S, et al. Meta-analysis of ischemia-modified albumin to rule out acute coronary syndromes in the emergency department. Am Heart J. 2006;152(2):253-62. [pmid: 16875905].
517 Peng Y, Wang HH. A meta-analysis of comparing fine-needle aspiration and frozen section for evaluating thyroid nodules. Diagn Cytopathol. 2008;36(12):916-20. [pmid: 18855886].
518 Peters NH, Borel Rinkes IH, Zuithoff NP, et al. Meta-analysis of MR imaging in the diagnosis of breast lesions. Radiology. 2008;246(1):116-24. [pmid: 18024435].
519 Petersen JR, Smith E, Okorodudu AO, et al. Comparison of four methods (L/S ratio, TDx FLM, lamellar bodies, PG) for fetal lung maturity using meta-analysis. Clin Lab Manage Rev. 1996;10(2):169-75. [pmid: 10172601].
520 Pfeiffer CD, Fine JP, Safdar N. Diagnosis of invasive aspergillosis using a galactomannan assay: a meta-analysis. Clin Infect Dis. 2006;42(10):1417-27. [pmid: 16619154].
521 Phillips KA. The use of meta-analysis in technology assessment: a meta-analysis of the enzyme immunosorbent assay human immunodeficiency virus antibody test. J Clin Epidemiol. 1991;44(9):925-31. [pmid: 1832441].
522 Picano E, Bedetti G, Varga A, et al. The comparable diagnostic accuracies of dobutamine-stress and dipyridamole-stress echocardiographies: a meta-analysis. Coron Artery Dis. 2000;11(2):151-9. [pmid: 10758817].
523 Picano E, Molinaro S, Pasanisi E. The diagnostic accuracy of pharmacological stress echocardiography for the assessment of coronary artery disease: a meta-analysis. Cardiovasc Ultrasound. 2008;6:30. [pmid: 18565214].
524 Pirozzo S, Papinczak T, Glasziou P. Whispered voice test for screening for hearing impairment in adults and children: systematic review. BMJ. 2003;327(7421):967. [pmid: 14576249].
525 Plevova P, Krepelova A, Papezova M, et al. Immunohistochemical detection of the hMLH1 and hMSH2 proteins in hereditary non-polyposis colon cancer and sporadic colon cancer. Neoplasma. 2004;51(4):275-84. [pmid: 15254659].
526 Plotkin M, Hautzel H, Krause BJ, et al. Implication of 2-18fluor-2-deoxyglucose positron emission tomography in the follow-up of Hurthle cell thyroid cancer. Thyroid. 2002;12(2):155-61. [pmid: 11916285].
527 Pretlove SJ, Fox CE, Khan KS, et al. Noninvasive methods of detecting fetal anaemia: a systematic review and meta-analysis. BJOG. 2009;116(12):1558-67. [pmid: 19681854].
528 Price CP, Newall RG, Boyd JC. Use of protein:creatinine ratio measurements on random urine samples for prediction of significant proteinuria: a systematic review. Clin Chem. 2005;51(9):1577-86. [pmid: 16020501].
529 Puli SR, Batapati Krishna Reddy J, Bechtold ML, et al. How good is endoscopic ultrasound for TNM staging of gastric cancers? A meta-analysis and systematic review. World J Gastroenterol. 2008;14(25):4011-9. [pmid: 18609685].
530 Puli SR, Batapati Krishna Reddy J, Bechtold ML, et al. Endoscopic ultrasound: it's accuracy in evaluating mediastinal lymphadenopathy? A meta-analysis and systematic review. World J Gastroenterol. 2008;14(19):3028-37. [pmid: 18494054].
531 Puli SR, Bechtold ML, Reddy JB, et al. How good is endoscopic ultrasound in differentiating various T stages of rectal cancer? Meta-analysis and systematic review. Ann Surg Oncol. 2009;16(2):254-65. [pmid: 19018597].
532 Puli SR, Reddy JB, Bechtold ML, et al. Staging accuracy of esophageal cancer by endoscopic ultrasound: a meta-analysis and systematic review. World J Gastroenterol. 2008;14(10):1479-90. [pmid: 18330935].
533 Puli SR, Reddy JB, Bechtold ML, et al. Accuracy of endoscopic ultrasound in the diagnosis of distal and celiac axis lymph node metastasis in esophageal cancer: a meta-analysis and systematic review. Dig Dis Sci. 2008;53(9):2405-14. [pmid: 18097752].
534 Puli SR, Reddy JB, Bechtold ML, et al. Accuracy of endoscopic ultrasound to diagnose nodal invasion by rectal cancers: a meta-analysis and systematic review. Ann Surg Oncol. 2009;16(5):1255-65. [pmid: 19219506].
535 Puli SR, Singh S, Hagedorn CH, et al. Diagnostic accuracy of EUS for vascular invasion in pancreatic and periampullary cancers: a meta-analysis and systematic review. Gastrointest Endosc. 2007;65(6):788-97. [pmid: 17350008].
536 Purkayastha S, Athanasiou T, Tekkis PP, et al. Magnetic resonance colonography vs computed tomography colonography for the diagnosis of colorectal cancer: an indirect comparison. Colorectal Dis. 2007;9(2):100-11. [pmid: 17223933].
537 Purkayastha S, Chow A, Athanasiou T, et al. Does serum procalcitonin have a role in evaluating the severity of acute pancreatitis? A question revisited. World J Surg. 2006;30(9):1713-21. [pmid: 16927057].
538 Purkayastha S, Tekkis PP, Athanasiou T, et al. Magnetic resonance colonography versus colonoscopy as a diagnostic investigation for colorectal cancer: a meta-analysis. Clin Radiol. 2005;60(9):980-9. [pmid: 16124980].
539 Purkayastha S, Tekkis PP, Athanasiou T, et al. Diagnostic precision of magnetic resonance imaging for preoperative prediction of the circumferential margin involvement in patients with rectal cancer. Colorectal Dis. 2007;9(5):402-11. [pmid: 17504336].
540 Quaglino P, Savoia P, Fierro MT, et al. Clinical significance of sequential tyrosinase expression in the peripheral blood of disease-free melanoma patients: a review of literature data. Melanoma Res. 2004;14(2):S17-9. [pmid: 15057052].
541 Quiroz R, Kucher N, Zou KH, et al. Clinical validity of a negative computed tomography scan in patients with suspected pulmonary embolism: a systematic review. JAMA. 2005;293(16):2012-7. [pmid: 15855435].
542 Raijmakers PG, Paul MA, Lips P. Sentinel node detection in patients with thyroid carcinoma: a meta-analysis. World J Surg. 2008;32(9):1961-7. [pmid: 18594904].
543 Rajpara SM, Botello AP, Townend J, et al. Systematic review of dermoscopy and digital dermoscopy/ artificial intelligence for the diagnosis of melanoma. Br J Dermatol. 2009;161(3):591-604. [pmid: 19302072].
544 Rao JK, Weinberger M, Oddone EZ, et al. The role of antineutrophil cytoplasmic antibody (c-ANCA) testing in the diagnosis of Wegener granulomatosis. A literature review and meta-analysis. Ann Intern Med. 1995;123(12):925-32. [pmid: 7486487].
545 Rasiah SV, Publicover M, Ewer AK, et al. A systematic review of the accuracy of first-trimester ultrasound examination for detecting major congenital heart disease. Ultrasound Obstet Gynecol. 2006;28(1):110-6. [pmid: 16795132].
546 Reed JF 3rd. Meta-analysis of the reliability of noninvasive carotid studies. Biomed Instrum Technol. 1991;25(6):465-71. [pmid: 1838017].
547 Reed WW, Byrd GS, Gates RH Jr., et al. Sputum gram's stain in community-acquired pneumococcal pneumonia. A meta-analysis. West J Med. 1996;165(4):197-204. [pmid: 8987424].
548 Reese GE, Constantinides VA, Simillis C, et al. Diagnostic precision of anti-Saccharomyces cerevisiae antibodies and perinuclear antineutrophil cytoplasmic antibodies in inflammatory bowel disease. Am J Gastroenterol. 2006;101(10):2410-22. [pmid: 16952282].
549 Revah A, Hannah ME, Sue-A-Quan AK. Fetal fibronectin as a predictor of preterm birth: an overview. Am J Perinatol. 1998;15(11):613-21. [pmid: 10064202].
550 Reznek L. The Rey 15-item memory test for malingering: a meta-analysis. Brain Inj. 2005;19(7):539-43. [pmid: 16134741].
551 Riquelme A, Calvo M, Salech F, et al. Value of adenosine deaminase (ADA) in ascitic fluid for the diagnosis of tuberculous peritonitis: a meta-analysis. J Clin Gastroenterol. 2006;40(8):705-10. [pmid: 16940883].
552 Roach ES. Tuberous sclerosis: function follows form. J Child Neurol. 1997;12(2):75-6. [pmid: 9075014].
553 Roberts AP, Childs SM, Rubin G, et al. Tests for Helicobacter pylori infection: a critical appraisal from primary care. Fam Pract. Suppl 2. 2000;17:S12-20. [pmid: 10960430].
554 Roddam AW, Duffy MJ, Hamdy FC, et al. Use of prostate-specific antigen (PSA) isoforms for the detection of prostate cancer in men with a PSA level of 2-10 ng/ml: systematic review and meta-analysis. Eur Urol. 2005;48(3):386-99. discussion 98-9. [pmid: 15982797].
555 Rodgers MA, Hempel S, Aho T, et al. Diagnostic tests used in the investigation of adult haematuria: A systematic review. BJU Int. 2006;98(6):1154-60. [pmid: 16879444].
556 Romagnuolo J, Bardou M, Rahme E, et al. Magnetic resonance cholangiopancreatography: a meta-analysis of test performance in suspected biliary disease. Ann Intern Med. 2003;139(7):547-57. [pmid: 14530225].
557 Roos JF, Doust J, Tett SE, et al. Diagnostic accuracy of cystatin C compared to serum creatinine for the estimation of renal dysfunction in adults and children—a meta-analysis. Clin Biochem. 2007;40(5-6):383-91. [pmid: 17316593].
558 Rosa MI, Medeiros LR, Bozzetti MC, et al. Accuracy of telomerase in cervical lesions: a systematic review. Int J Gynecol Cancer. 2007;17(6):1205-14. [pmid: 17506842].
559 Rosado B, Menzies S, Harbauer A, et al. Accuracy of computer diagnosis of melanoma: a quantitative meta-analysis. Arch Dermatol. 2003;139(3):361-7. discussion 6. [pmid: 12622631].
560 Rosenberg D, Cretin S. Use of meta-analysis to evaluate tolonium chloride in oral cancer screening. Oral Surg Oral Med Oral Pathol. 1989;67(5):621-7. [pmid: 2654801].
561 Rosman AS, Korsten MA. Meta-analysis comparing CT colonography, air contrast barium enema, and colonoscopy. Am J Med. 2007;120(3):203-10 e4. [pmid: 17349438].
562 Ross SD, Sheinhait IA, Harrison KJ, et al. Systematic review and meta-analysis of the literature regarding the diagnosis of sleep apnea. Sleep. 2000;23(4):519-32. [pmid: 10875559].
563 Rostom A, Dube C, Cranney A, et al. The diagnostic accuracy of serologic tests for celiac disease: a systematic review. Gastroenterology. 2005;128(4 Suppl 1):S38-46. [pmid: 15825125].
564 Roy PM, Colombet I, Durieux P, et al. Systematic review and meta-analysis of strategies for the diagnosis of suspected pulmonary embolism. BMJ. 2005;331(7511):259. [pmid: 16052017].
565 Rud B, Hilden J, Hyldstrup L, et al. Performance of the Osteoporosis Self-Assessment Tool in ruling out low bone mineral density in postmenopausal women: a systematic review. Osteoporos Int. 2007;18(9):1177-87. [pmid: 17361324].
566 Rud B, Hilden J, Hyldstrup L, et al. The Osteoporosis Self-Assessment Tool versus alternative tests for selecting postmenopausal women for bone mineral density assessment: a comparative systematic review of accuracy. Osteoporos Int. 2009;20(4):599-607. [pmid: 18716823].
567 Sadowski DC, Rabeneck L. Gastric ulcers at endoscopy: brush, biopsy, or both?. Am J Gastroenterol. 1997;92(4):608-13. [pmid: 9128308].
568 Safdar N, Fine JP, Maki DG. Meta-analysis: methods for diagnosing intravascular device-related bloodstream infection. Ann Intern Med. 2005;142(6):451-66. [pmid: 15767623].
569 Safriel Y, Zinn H. CT pulmonary angiography in the detection of pulmonary emboli: a meta-analysis of sensitivities and specificities. Clin Imaging. 2002;26(2):101-5. [pmid: 11852216].
570 Sampson FC, Goodacre SW, Thomas SM, et al. The accuracy of MRI in diagnosis of suspected deep vein thrombosis: systematic review and meta-analysis. Eur Radiol. 2007;17(1):175-81. [pmid: 16628439].
571 Samson DJ, Flamm CR, Pisano ED, et al. Should FDG PET be used to decide whether a patient with an abnormal mammogram or breast finding at physical examination should undergo biopsy?. Acad Radiol. 2002;9(7):773-83. [pmid: 12139091].
572 Sanchez-Ramos L, Delke I, Zamora J, et al. Fetal fibronectin as a short-term predictor of preterm birth in symptomatic patients: a meta-analysis. Obstet Gynecol. 2009;114(3):631-40. [pmid: 19701045].
573 Sanders S, Barnett A, Correa-Velez I, et al. Systematic review of the diagnostic accuracy of C-reactive protein to detect bacterial infection in nonhospitalized infants and children with fever. J Pediatr. 2008;153(4):570-4. [pmid: 18534215].
574 Sarmiento OL, Weigle KA, Alexander J, et al. Assessment by meta-analysis of PCR for diagnosis of smear-negative pulmonary tuberculosis. J Clin Microbiol. 2003;41(7):3233-40. [pmid: 12843069].
575 Sarwar A, Shaw LJ, Shapiro MD, et al. Diagnostic and prognostic value of absence of coronary artery calcification. JACC Cardiovasc Imaging. 2009;2(6):675-88. [pmid: 19520336].
576 Sauerland S, Bouillon B, Rixen D, et al. The reliability of clinical examination in detecting pelvic fractures in blunt trauma patients: a meta-analysis. Arch Orthop Trauma Surg. 2004;124(2):123-8. [pmid: 14745568].
577 Scheidler J, Hricak H, Yu KK, et al. Radiological evaluation of lymph node metastases in patients with cervical cancer. A meta-analysis. JAMA. 1997;278(13):1096-101. [pmid: 9315770].
578 Schinkel AF, Bax JJ, Geleijnse ML, et al. Noninvasive evaluation of ischaemic heart disease: myocardial perfusion imaging or stress echocardiography?. Eur Heart J. 2003;24(9):789-800. [pmid: 12727146].
579 Scholten RJ, Deville WL, Opstelten W, et al. The accuracy of physical diagnostic tests for assessing meniscal lesions of the knee: a meta-analysis. J Fam Pract. 2001;50(11):938-44. [pmid: 11711009].
580 Scholten RJ, Opstelten W, van der Plas CG, et al. Accuracy of physical diagnostic tests for assessing ruptures of the anterior cruciate ligament: a meta-analysis. J Fam Pract. 2003;52(9):689-94. [pmid: 12967539].
581 Schreiber G, McCrory DC. Performance characteristics of different modalities for diagnosis of suspected lung cancer: summary of published evidence. Chest. 2003;123(1 Suppl):115S-28S. [pmid: 12527571].
582 Schuijf JD, Bax JJ, Shaw LJ, et al. Meta-analysis of comparative diagnostic performance of magnetic resonance imaging and multislice computed tomography for noninvasive coronary angiography. Am Heart J. 2006;151(2):404-11. [pmid: 16442907].
583 Schwimmer J, Essner R, Patel A, et al. A review of the literature for whole-body FDG PET in the management of patients with melanoma. Q J Nucl Med. 2000;44(2):153-67. [pmid: 10967625].
584 Scouller K, Conigrave KM, Macaskill P, et al. Should we use carbohydrate-deficient transferrin instead of gamma-glutamyltransferase for detecting problem drinkers? A systematic review and metaanalysis. Clin Chem. 2000;46(12):1894-902. [pmid: 11106319].
585 Selman TJ, Luesley DM, Acheson N, et al. A systematic review of the accuracy of diagnostic tests for inguinal lymph node status in vulvar cancer. Gynecol Oncol. 2005;99(1):206-14. [pmid: 16081147].
586 Selman TJ, Mann C, Zamora J, et al. Diagnostic accuracy of tests for lymph node status in primary cervical cancer: a systematic review and meta-analysis. CMAJ. 2008;178(7):855-62. [pmid: 18362381].
587 Selman TJ, Mann CH, Zamora J, et al. A systematic review of tests for lymph node status in primary endometrial cancer. BMC Womens Health. 2008;8:8. [pmid: 18457596].
588 Shafiq N, Malhotra S, Bhasin DK, et al. Estimating the diagnostic accuracy of procalcitonin as a marker of the severity of acute pancreatitis: a meta-analytic approach. JOP. 2005;6(3):231-7. [pmid: 15883473].
589 Shaheen AA, Myers RP. Diagnostic accuracy of the aspartate aminotransferase-to-platelet ratio index for the prediction of hepatitis C-related fibrosis: a systematic review. Hepatology. 2007;46(3):912-21. [pmid: 17705266].
590 Shaheen AA, Myers RP. Systematic review and meta-analysis of the diagnostic accuracy of fibrosis marker panels in patients with HIV/hepatitis C coinfection. HIV Clin Trials. 2008;9(1):43-51. [pmid: 18215981].
591 Shaheen AA, Wan AF, Myers RP. FibroTest and FibroScan for the prediction of hepatitis C-related fibrosis: a systematic review of diagnostic test accuracy. Am J Gastroenterol. 2007;102(11):2589-600. [pmid: 17850410].
592 Shaikh N, Morone NE, Lopez J, et al. Does this child have a urinary tract infection?. JAMA. 2007;298(24):2895-904. [pmid: 18159059].
593 Sharpless KE, O'Sullivan DM, Schnatz PF. The utility of human papillomavirus testing in the management of atypical glandular cells on cytology. J Low Genit Tract Dis. 2009;13(2):72-8. [pmid: 19387126].
594 Shaw LJ, Peterson ED, Kesler K, et al. A metaanalysis of predischarge risk stratification after acute myocardial infarction with stress electrocardiographic, myocardial perfusion, and ventricular function imaging. Am J Cardiol. 1996;78(12):1327-37. [pmid: 8970402].
595 Shea JA, Berlin JA, Escarce JJ, et al. Revised estimates of diagnostic test sensitivity and specificity in suspected biliary tract disease. Arch Intern Med. 1994;154(22):2573-81. [pmid: 7979854].
596 Shi HZ, Liang QL, Jiang J, et al. Diagnostic value of carcinoembryonic antigen in malignant pleural effusion: a meta-analysis. Respirology. 2008;13(4):518-27. [pmid: 18422869].
597 Shie P, Cardarelli R, Brandon D, et al. Meta-analysis: comparison of F-18 Fluorodeoxyglucose-positron emission tomography and bone scintigraphy in the detection of bone metastases in patients with breast cancer. Clin Nucl Med. 2008;33(2):97-101. [pmid: 18209527].
598 Shiga T, Wajima Z, Apfel CC, et al. Diagnostic accuracy of transesophageal echocardiography, helical computed tomography, and magnetic resonance imaging for suspected thoracic aortic dissection: systematic review and meta-analysis. Arch Intern Med. 2006;166(13):1350-6. [pmid: 16831999].
599 Shiga T, Wajima Z, Inoue T, et al. Predicting difficult intubation in apparently normal patients: a meta-analysis of bedside screening test performance. Anesthesiology. 2005;103(2):429-37. [pmid: 16052126].
600 Shimada T, Noguchi Y, Jackson JL, et al. Systematic review and metaanalysis: urinary antigen tests for Legionellosis. Chest. 2009;136(6):1576-85. [pmid: 19318671].
601 Siegman-Igra Y, Anglim AM, Shapiro DE, et al. Diagnosis of vascular catheter-related bloodstream infection: a meta-analysis. J Clin Microbiol. 1997;35(4):928-36. [pmid: 9157155].
602 Silvestri GA, Littenberg B, Colice GL. The clinical evaluation for detecting metastatic lung cancer. A meta-analysis. Am J Respir Crit Care Med. 1995;152(1):225-30. [pmid: 7599828].
603 Simon L, Gauvin F, Amre DK, et al. Serum procalcitonin and C-reactive protein levels as markers of bacterial infection: a systematic review and meta-analysis. Clin Infect Dis. 2004;39(2):206-17. [pmid: 15307030].
604 Singal A, Volk ML, Waljee A, et al. Meta-analysis: surveillance with ultrasound for early-stage hepatocellular carcinoma in patients with cirrhosis. Aliment Pharmacol Ther. 2009;30(1):37-47. [pmid: 19392863].
605 Sinuff T, Adhikari NK, Cook DJ, et al. Mortality predictions in the intensive care unit: comparing physicians with scoring systems. Crit Care Med. 2006;34(3):878-85. [pmid: 16505667].
606 Skupski DW, Rosenberg CR, Eglinton GS. Intrapartum fetal stimulation tests: a meta-analysis. Obstet Gynecol. 2002;99(1):129-34. [pmid: 11777523].
607 Sloka JS, Hollett PD, Mathews M. A quantitative review of the use of FDG-PET in the axillary staging of breast cancer. Med Sci Monit. 2007;13(3):RA37-46. [pmid: 17325645].
608 Smart SC, Sagar KB. Diagnostic and prognostic use of stress echocardiography in stable patients. Echocardiography. 2000;17(5):465-77. [pmid: 10979024].
609 Smith-Bindman R, Hosmer W, Feldstein VA, et al. Second-trimester ultrasound to detect fetuses with Down syndrome: a meta-analysis. JAMA. 2001;285(8):1044-55. [pmid: 11209176].
610 Smith-Bindman R, Kerlikowske K, Feldstein VA, et al. Endovaginal ultrasound to exclude endometrial cancer and other endometrial abnormalities. JAMA. 1998;280(17):1510-7. [pmid: 9809732].
611 Sodeck G, Domanovits H, Schillinger M, et al. D-dimer in ruling out acute aortic dissection: a systematic review and prospective cohort study. Eur Heart J. 2007;28(24):3067-75. [pmid: 17986466].
612 Solomon DH, Simel DL, Bates DW, et al. The rational clinical examination. Does this patient have a torn meniscus or ligament of the knee? Value of the physical examination. JAMA. 2001;286(13):1610-20. [pmid: 11585485].
613 Song IH, Carrasco-Fernandez J, Rudwaleit M, et al. The diagnostic value of scintigraphy in assessing sacroiliitis in ankylosing spondylitis: a systematic literature research. Ann Rheum Dis. 2008;67(11):1535-40. [pmid: 18230629].
614 Song JM, Kim CB, Chung HC, et al. Prostate-specific antigen, digital rectal examination and transrectal ultrasonography: a meta-analysis for this diagnostic triad of prostate cancer in symptomatic korean men. Yonsei Med J. 2005;46(3):414-24. [pmid: 15988815].
615 Sonnad SS, Langlotz CP, Schwartz JS. Accuracy of MR imaging for staging prostate cancer: a meta-analysis to examine the effect of technologic change. Acad Radiol. 2001;8(2):149-57. [pmid: 11227643].
616 Sosna J, Sella T, Sy O, et al. Critical analysis of the performance of double-contrast barium enema for detecting colorectal polyps > or = 6 mm in the era of CT colonography. AJR Am J Roentgenol. 2008;190(2):374-85. [pmid: 18212223].
617 Sotiriadis A, Makrydimas G, Ioannidis JP. Diagnostic performance of intracardiac echogenic foci for Down syndrome: a meta-analysis. Obstet Gynecol. 2003;101(5 Pt 1):1009-16. [pmid: 12738165].
618 Spencer-Green G, Alter D, Welch HG. Test performance in systemic sclerosis: anti-centromere and anti-Scl-70 antibodies. Am J Med. 1997;103(3):242-8. [pmid: 9316557].
619 Spitzmiller RE, Phillips T, Meinzen-Derr J, et al. Amplitude-integrated EEG is useful in predicting neurodevelopmental outcome in full-term infants with hypoxic-ischemic encephalopathy: a meta-analysis. J Child Neurol. 2007;22(9):1069-78. [pmid: 17890403].
620 St John A, Boyd JC, Lowes AJ, et al. The use of urinary dipstick tests to exclude urinary tract infection: a systematic review of the literature. Am J Clin Pathol. 2006;126(3):428-36. [pmid: 16880133].
621 Stein PD, Beemath A, Kayali F, et al. Multidetector computed tomography for the diagnosis of coronary artery disease: a systematic review. Am J Med. 2006;119(3):203-16. [pmid: 16490463].
622 Stein PD, Hull RD, Patel KC, et al. D-dimer for the exclusion of acute venous thrombosis and pulmonary embolism: a systematic review. Ann Intern Med. 2004;140(8):589-602. [pmid: 15096330].
623 Stein PD, Yaekoub AY, Matta F, et al. 64-slice CT for diagnosis of coronary artery disease: a systematic review. Am J Med. 2008;121(8):715-25. [pmid: 18691486].
624 Steingart KR, Dendukuri N, Henry M, et al. Performance of purified antigens for serodiagnosis of pulmonary tuberculosis: a meta-analysis. Clin Vaccine Immunol. 2009;16(2):260-76. [pmid: 19052159].
625 Steingart KR, Henry M, Laal S, et al. A systematic review of commercial serological antibody detection tests for the diagnosis of extrapulmonary tuberculosis. Postgrad Med J. 2007;83(985):705-12. [pmid: 17989270].
626 Steingart KR, Henry M, Laal S, et al. Commercial serological antibody detection tests for the diagnosis of pulmonary tuberculosis: a systematic review. PLoS Med. 2007;4(6):e202. [pmid: 17564490].
627 Steingart KR, Henry M, Ng V, et al. Fluorescence versus conventional sputum smear microscopy for tuberculosis: a systematic review. Lancet Infect Dis. 2006;6(9):570-81. [pmid: 16931408].
628 Steingart KR, Ng V, Henry M, et al. Sputum processing methods to improve the sensitivity of smear microscopy for tuberculosis: a systematic review. Lancet Infect Dis. 2006;6(10):664-74. [pmid: 17008175].
629 Stengel D, Bauwens K, Sehouli J, et al. Systematic review and meta-analysis of emergency ultrasonography for blunt abdominal trauma. Br J Surg. 2001;88(7):901-12. [pmid: 11442520].
630 Stevens C, Lee JK, Sadatsafavi M, et al. Pediatric thyroid fine-needle aspiration cytology: a meta-analysis. J Pediatr Surg. 2009;44(11):2184-91. [pmid: 19944231].
631 Sulik SM, Kroeger K, Schultz JK, et al. Are fluid-based cytologies superior to the conventional Papanicolaou test? A systematic review. J Fam Pract. 2001;50(12):1040-6. [pmid: 11742605].
632 Sun Z, Davidson R, Lin CH. Multi-detector row CT angiography in the assessment of coronary in-stent restenosis: a systematic review. Eur J Radiol. 2009;69(3):489-95. [pmid: 18162351].
633 Sun Z, Jiang W. Diagnostic value of multislice computed tomography angiography in coronary artery disease: a meta-analysis. Eur J Radiol. 2006;60(2):279-86. [pmid: 16887313].
634 Sun Z, Lin C, Davidson R, et al. Diagnostic value of 64-slice CT angiography in coronary artery disease: a systematic review. Eur J Radiol. 2008;67(1):78-84. [pmid: 17766073].
635 Swart P, Mol BW, van der Veen F, et al. The accuracy of hysterosalpingography in the diagnosis of tubal pathology: a meta-analysis. Fertil Steril. 1995;64(3):486-91. [pmid: 7641899].
636 Szadek KM, van der Wurff P, van Tulder MW, et al. Diagnostic validity of criteria for sacroiliac joint pain: a systematic review. J Pain. 2009;10(4):354-68. [pmid: 19101212].
637 Tabas JA, Rodriguez RM, Seligman HK, et al. Electrocardiographic criteria for detecting acute myocardial infarction in patients with left bundle branch block: a meta-analysis. Ann Emerg Med. 2008;52(4):329-36 e1. [pmid: 18342992].
638 Talwalkar JA, Kurtz DM, Schoenleber SJ, et al. Ultrasound-based transient elastography for the detection of hepatic fibrosis: systematic review and meta-analysis. Clin Gastroenterol Hepatol. 2007;5(10):1214-20. [pmid: 17916549].
639 Tamariz LJ, Eng J, Segal JB, et al. Usefulness of clinical prediction rules for the diagnosis of venous thromboembolism: a systematic review. Am J Med. 2004;117(9):676-84. [pmid: 15501206].
640 Tan E, Anstee A, Koh DM, et al. Diagnostic precision of endoanal MRI in the detection of anal sphincter pathology: a meta-analysis. Int J Colorectal Dis. 2008;23(6):641-51. [pmid: 18330582].
641 Tan E, Gouvas N, Nicholls RJ, et al. Diagnostic precision of carcinoembryonic antigen in the detection of recurrence of colorectal cancer. Surg Oncol. 2009;18(1):15-24. [pmid: 18619834].
642 Tan KT, van Beek EJ, Brown PW, et al. Magnetic resonance angiography for the diagnosis of renal artery stenosis: a meta-analysis. Clin Radiol. 2002;57(7):617-24. [pmid: 12096862].
643 Tandon S, Shahab R, Benton JI, et al. Fine-needle aspiration cytology in a regional head and neck cancer center: comparison with a systematic review and meta-analysis. Head Neck. 2008;30(9):1246-52. [pmid: 18528906].
644 Tang BM, Eslick GD, Craig JC, et al. Accuracy of procalcitonin for sepsis diagnosis in critically ill patients: systematic review and meta-analysis. Lancet Infect Dis. 2007;7(3):210-7. [pmid: 17317602].
645 Tebas P, Nease RF, Storch GA. Use of the polymerase chain reaction in the diagnosis of herpes simplex encephalitis: a decision analysis model. Am J Med. 1998;105(4):287-95. [pmid: 9809689].
646 Temmerman OP, Heyligers IC, Teule GJ, et al. The value of contrast and subtraction arthrography in the assessment of aseptic loosening of total hip prostheses: a meta-analysis. Eur J Radiol. 2005;56(1):113-9. [pmid: 15893898].
647 Temmerman OP, Raijmakers PG, Berkhof J, et al. Accuracy of diagnostic imaging techniques in the diagnosis of aseptic loosening of the femoral component of a hip prosthesis: a meta-analysis. J Bone Joint Surg Br. 2005;87(6):781-5. [pmid: 15911658].
648 Temmerman OP, Raijmakers PG, Deville WL, et al. The use of plain radiography, subtraction arthrography, nuclear arthrography, and bone scintigraphy in the diagnosis of a loose acetabular component of a total hip prosthesis: a systematic review. J Arthroplasty. 2007;22(6):818-27. [pmid: 17826271].
649 Teng CL, Ng CJ, Nik-Sherina H, et al. The accuracy of mother's touch to detect fever in children: a systematic review. J Trop Pediatr. 2008;54(1):70-3. [pmid: 18039678].
650 Tenner S, Dubner H, Steinberg W. Predicting gallstone pancreatitis with laboratory parameters: a meta-analysis. Am J Gastroenterol. 1994;89(10):1863-6. [pmid: 7942684].
651 Terasawa T, Blackmore CC, Bent S, et al. Systematic review: computed tomography and ultrasonography to detect acute appendicitis in adults and adolescents. Ann Intern Med. 2004;141(7):537-46. [pmid: 15466771].
652 Terasawa T, Lau J, Bardet S, et al. Fluorine-18-fluorodeoxyglucose positron emission tomography for interim response assessment of advanced-stage Hodgkin's lymphoma and diffuse large B-cell lymphoma: a systematic review. J Clin Oncol. 2009;27(11):1906-14. [pmid: 19273713].
653 Terasawa T, Nihashi T, Hotta T, et al. 18F-FDG PET for posttherapy assessment of Hodgkin's disease and aggressive non-Hodgkin's lymphoma: a systematic review. J Nucl Med. 2008;49(1):13-21. [pmid: 18077527].
654 Termaat MF, Raijmakers PG, Scholten HJ, et al. The accuracy of diagnostic imaging for the assessment of chronic osteomyelitis: a systematic review and meta-analysis. J Bone Joint Surg Am. 2005;87(11):2464-71. [pmid: 16264122].
655 Tew K, Irwig L, Matthews A, et al. Meta-analysis of sentinel node imprint cytology in breast cancer. Br J Surg. 2005;92(9):1068-80. [pmid: 16106479].
656 Thangaratinam S, Coomarasamy A, O'Mahony F, Sharp S, Zamora J, Khan KS, et al. Estimation of proteinuria as a predictor of complications of pre-eclampsia: a systematic review. BMC Med. 2009;7:10. [pmid: 19317889].
657 Thangaratinam S, Daniels J, Ewer AK, et al. Accuracy of pulse oximetry in screening for congenital heart disease in asymptomatic newborns: a systematic review. Arch Dis Child Fetal Neonatal Ed. 2007;92(3):F176-80. [pmid: 17344253].
658 Thangaratinam S, Ismail KM, Sharp S, et al. Accuracy of serum uric acid in predicting complications of pre-eclampsia: a systematic review. BJOG. 2006;113(4):369-78. [pmid: 16553648].
659 Thomas SM, Goodacre SW, Sampson FC, et al. Diagnostic value of CT for deep vein thrombosis: results of a systematic review and meta-analysis. Clin Radiol. 2008;63(3):299-304. [pmid: 18275870].
660 Thorell LH. Valid electrodermal hyporeactivity for depressive suicidal propensity offers links to cognitive theory. Acta Psychiatr Scand. 2009;119(5):338-49. [pmid: 19245680].
661 Trochez-Martinez RD, Smith P, Lamont RF. Use of C-reactive protein as a predictor of chorioamnionitis in preterm prelabour rupture of membranes: a systematic review. BJOG. 2007;114(7):796-801. [pmid: 17567416].
662 Trowbridge RL, Rutkowski NK, Shojania KG. Does this patient have acute cholecystitis?. JAMA. 2003;289(1):80-6. [pmid: 12503981].
663 Tsao H, Nadiminti U, Sober AJ, et al. A meta-analysis of reverse transcriptase-polymerase chain reaction for tyrosinase mRNA as a marker for circulating tumor cells in cutaneous melanoma. Arch Dermatol. 2001;137(3):325-30. [pmid: 11255333].
664 Tse F, Liu L, Barkun AN, et al. EUS: a meta-analysis of test performance in suspected choledocholithiasis. Gastrointest Endosc. 2008;67(2):235-44. [pmid: 18226685].
665 Tsushima Y, Takahashi-Taketomi A, Endo K. Magnetic resonance (MR) differential diagnosis of breast tumors using apparent diffusion coefficient (ADC) on 1.5-T. J Magn Reson Imaging. 2009;30(2):249-55. [pmid: 19629992].
666 Tuon FF. A systematic literature review on the diagnosis of invasive aspergillosis using polymerase chain reaction (PCR) from bronchoalveolar lavage clinical samples. Rev Iberoam Micol. 2007;24(2):89-94. [pmid: 17604424].
667 Tuon FF, Litvoc MN, Lopes MI. Adenosine deaminase and tuberculous pericarditis—a systematic review with meta-analysis. Acta Trop. 2006;99(1):67-74. [pmid: 16950165].
668 Urbach DR, Khajanchee YS, Jobe BA, et al. Cost-effective management of common bile duct stones: a decision analysis of the use of endoscopic retrograde cholangiopancreatography (ERCP), intraoperative cholangiography, and laparoscopic bile duct exploration. Surg Endosc. 2001;15(1):4-13. [pmid: 11178753].
669 Uzzan B, Cohen R, Nicolas P, et al. Procalcitonin as a diagnostic test for sepsis in critically ill adults and after surgery or trauma: a systematic review and meta-analysis. Crit Care Med. 2006;34(7):1996-2003. [pmid: 16715031].
670 Vakil N, Moayyedi P, Fennerty MB, et al. Limited value of alarm features in the diagnosis of upper gastrointestinal malignancy: systematic review and meta-analysis. Gastroenterology. 2006;131(2):390-401. quiz 659-60. [pmid: 16890592].
671 van Beek EJ, Brouwers EM, Song B, et al. Lung scintigraphy and helical computed tomography for the diagnosis of pulmonary embolism: a meta-analysis. Clin Appl Thromb Hemost. 2001;7(2):87-92. [pmid: 11292198].
672 van de Laar R, van der Ham DP, Oei SG, et al. Accuracy of C-reactive protein determination in predicting chorioamnionitis and neonatal infection in pregnant women with premature rupture of membranes: a systematic review. Eur J Obstet Gynecol Reprod Biol. 2009;147(2):124-9. [pmid: 19819609].
673 van de Lande J, Torrenga B, Raijmakers PG, et al. Sentinel lymph node detection in early stage uterine cervix carcinoma: a systematic review. Gynecol Oncol. 2007;106(3):604-13. [pmid: 17628644].
674 van den Broek FJ, Reitsma JB, Curvers WL, et al. Systematic review of narrow-band imaging for the detection and differentiation of neoplastic and nonneoplastic lesions in the colon (with videos). Gastrointest Endosc. 2009;69(1):124-35. [pmid: 19111693].
675 Van Der Horst-Schrivers AN, Jager PL, Boezen HM, et al. Iodine-123 metaiodobenzylguanidine scintigraphy in localising phaeochromocytomas—experience and meta-analysis. Anticancer Res. 2006;26(2B):1599-604. [pmid: 16619578].
676 van der Meer V, Neven AK, van den Broek PJ, et al. Diagnostic value of C reactive protein in infections of the lower respiratory tract: systematic review. BMJ. 2005;331(7507):26. [pmid: 15979984].
677 van der Ploeg IM, Nieweg OE, van Rijk MC, et al. Axillary recurrence after a tumour-negative sentinel node biopsy in breast cancer patients: A systematic review and meta-analysis of the literature. Eur J Surg Oncol. 2008;34(12):1277-84. [pmid: 18406100].
678 van der Zaag-Loonen HJ, Dikkers R, de Bock GH, et al. The clinical value of a negative multi-detector computed tomographic angiography in patients suspected of coronary artery disease: A meta-analysis. Eur Radiol. 2006;16(12):2748-56. [pmid: 16718450].
679 van Deurzen CH, Vriens BE, Tjan-Heijnen VC, et al. Accuracy of sentinel node biopsy after neoadjuvant chemotherapy in breast cancer patients: a systematic review. Eur J Cancer. 2009;45(18):3124-30. [pmid: 19716287].
680 van Dongen H, de Kroon CD, Jacobi CE, et al. Diagnostic hysteroscopy in abnormal uterine bleeding: a systematic review and meta-analysis. BJOG. 2007;114(6):664-75. [pmid: 17516956].
681 van Gelder JM. Computed tomographic angiography for detecting cerebral aneurysms: implications of aneurysm size distribution for the sensitivity, specificity, and likelihood ratios. Neurosurgery. 2003;53(3):597-605. discussion -6. [pmid: 12943576].
682 van Randen A, Bipat S, Zwinderman AH, et al. Acute appendicitis: meta-analysis of diagnostic performance of CT and graded compression US related to prevalence of disease. Radiology. 2008;249(1):97-106. [pmid: 18682583].
683 van Rijkom HM, Verdonschot EH. Factors involved in validity measurements of diagnostic tests for approximal caries—a meta-analysis. Caries Res. 1995;29(5):364-70. [pmid: 8521438].
684 van Schaik IN, Bossuyt PM, Brand A, et al. Diagnostic value of GM1 antibodies in motor neuron disorders and neuropathies: a meta-analysis. Neurology. 1995;45(8):1570-7. [pmid: 7644057].
685 van Vliet EP, Heijenbrok-Kal MH, Hunink MG, et al. Staging investigations for oesophageal cancer: a meta-analysis. Br J Cancer. 2008;98(3):547-57. [pmid: 18212745].
686 van Weert JM, Repping S, Van Voorhis BJ, et al. Performance of the postwash total motile sperm count as a predictor of pregnancy at the time of intrauterine insemination: a meta-analysis. Fertil Steril. 2004;82(3):612-20. [pmid: 15374704].
687 van Westreenen HL, Westerterp M, Bossuyt PM, et al. Systematic review of the staging performance of 18F-fluorodeoxyglucose positron emission tomography in esophageal cancer. J Clin Oncol. 2004;22(18):3805-12. [pmid: 15365078].
688 Van Zaane B, Zuithoff NP, Reitsma JB, et al. Meta-analysis of the diagnostic accuracy of transesophageal echocardiography for assessment of atherosclerosis in the ascending aorta in patients undergoing cardiac surgery. Acta Anaesthesiol Scand. 2008;52(9):1179-87. [pmid: 18823455].
689 Vanezis AP, Bhopal R. Validity of electrocardiographic classification of left ventricular hypertrophy across adult ethnic groups with echocardiography as a standard. J Electrocardiol. 2008;41(5):404-12. [pmid: 18452942].
690 Vanhoenacker PK, Decramer I, Bladt O, et al. Detection of non-ST-elevation myocardial infarction and unstable angina in the acute setting: meta-analysis of diagnostic performance of multi-detector computed tomographic angiography. BMC Cardiovasc Disord. 2007;7:39. [pmid: 18093295].
691 Vanhoenacker PK, Decramer I, Bladt O, et al. Multidetector computed tomography angiography for assessment of in-stent restenosis: meta-analysis of diagnostic performance. BMC Med Imaging. 2008;8:14. [pmid: 18671850].
692 Vanhoenacker PK, Heijenbrok-Kal MH, Van Heste R, et al. Diagnostic performance of multidetector CT angiography for assessment of coronary artery disease: meta-analysis. Radiology. 2007;244(2):419-28. [pmid: 17641365].
693 Varonen H, Makela M, Savolainen S, et al. Comparison of ultrasound, radiography, and clinical examination in the diagnosis of acute maxillary sinusitis: a systematic review. J Clin Epidemiol. 2000;53(9):940-8. [pmid: 11004420].
694 Vasbinder GB, Nelemans PJ, Kessels AG, et al. Diagnostic tests for renal artery stenosis in patients suspected of having renovascular hypertension: a meta-analysis. Ann Intern Med. 2001;135(6):401-11. [pmid: 11560453].
695 Vasquez TE, Rimkus DS, Hass MG, et al. Efficacy of morphine sulfate-augmented hepatobiliary imaging in acute cholecystitis. J Nucl Med Technol. 2000;28(3):153-5. [pmid: 11001495].
696 Vercammen MJ, Verloes A, Van de Velde H, et al. Accuracy of soluble human leukocyte antigen-G for predicting pregnancy among women undergoing infertility treatment: meta-analysis. Hum Reprod Update. 2008;14(3):209-18. [pmid: 18390888].
697 Verkooijen HM, Peeters PH, Buskens E, et al. Diagnostic accuracy of large-core needle biopsy for nonpalpable breast disease: a meta-analysis. Br J Cancer. 2000;82(5):1017-21. [pmid: 10737383].
698 Verma D, Kapadia A, Eisen GM, et al. EUS vs MRCP for detection of choledocholithiasis. Gastrointest Endosc. 2006;64(2):248-54. [pmid: 16860077].
699 Vestergaard ME, Macaskill P, Holt PE, et al. Dermoscopy compared with naked eye examination for the diagnosis of primary melanoma: a meta-analysis of studies performed in a clinical setting. Br J Dermatol. 2008;159(3):669-76. [pmid: 18616769].
700 Vijayasankar D, Boyle AA, Atkinson P. Can the Ottawa knee rule be applied to children? A systematic review and meta-analysis of observational studies. Emerg Med J. 2009;26(4):250-3. [pmid: 19307383].
701 Virgili G, Menchini F, Dimastrogiovanni AF, et al. Optical coherence tomography versus stereoscopic fundus photography or biomicroscopy for diagnosing diabetic macular edema: a systematic review. Invest Ophthalmol Vis Sci. 2007;48(11):4963-73. [pmid: 17962446].
702 Visser K, Hunink MG. Peripheral arterial disease: gadolinium-enhanced MR angiography versus color-guided duplex US—a meta-analysis. Radiology. 2000;216(1):67-77. [pmid: 10887229].
703 Vlaar AM, Bouwmans A, Mess WH, et al. Transcranial duplex in the differential diagnosis of parkinsonian syndromes: a systematic review. J Neurol. 2009;256(4):530-8. [pmid: 19224315].
704 Vlaar AM, van Kroonenburgh MJ, Kessels AG, et al. Meta-analysis of the literature on diagnostic accuracy of SPECT in parkinsonian syndromes. BMC Neurol. 2007;7:27. [pmid: 17764571].
705 von Roon AC, Karamountzos L, Purkayastha S, et al. Diagnostic precision of fecal calprotectin for inflammatory bowel disease and colorectal malignancy. Am J Gastroenterol. 2007;102(4):803-13. [pmid: 17324124].
706 Vroomen PC, de Krom MC, Knottnerus JA. Diagnostic value of history and physical examination in patients suspected of sciatica due to disc herniation: a systematic review. J Neurol. 1999;246(10):899-906. [pmid: 10552236].
707 Wald DS, Bestwick JP. Carotid ultrasound screening for coronary heart disease: results based on a meta-analysis of 18 studies and 44,861 subjects. J Med Screen. 2009;16(3):147-54. [pmid: 19805756].
708 Wald DS, Bestwick JP, Wald NJ. Child-parent screening for familial hypercholesterolaemia: screening strategy based on a meta-analysis. BMJ. 2007;335(7620):599. [pmid: 17855284].
709 Wald NJ, Kennard A, Hackshaw AK. First trimester serum screening for Down's syndrome. Prenat Diagn. 1995;15(13):1227-40. [pmid: 8710764].
710 Walleser S, Griffiths A, Lord SJ, et al. What is the value of computered tomography colonography in patients screening positive for fecal occult blood? A systematic review and economic evaluation. Clin Gastroenterol Hepatol. 2007;5(12):1439-46. quiz 368. [pmid: 18054752].
711 Walton DM, Sadi J. Identifying SLAP lesions: a meta-analysis of clinical tests and exercise in clinical reasoning. Phys Ther Sport. 2008;9(4):167-76. [pmid: 19083717].
712 Wan Y, Xu YY, Jiang JH, et al. Chinese literature associated with diagnosis of Helicobacter pylori. World J Gastroenterol. 2004;10(2):231-3. [pmid: 14716829].
713 Wancata J, Alexandrowicz R, Marquart B, et al. The criterion validity of the Geriatric Depression Scale: a systematic review. Acta Psychiatr Scand. 2006;114(6):398-410. [pmid: 17087788].
714 Wang P, Guo YM, Liu M, et al. A meta-analysis of the accuracy of prostate cancer studies which use magnetic resonance spectroscopy as a diagnostic tool. Korean J Radiol. 2008;9(5):432-8. [pmid: 18838853].
715 Wang WH, Huang JQ, Zheng GF, et al. Is proton pump inhibitor testing an effective approach to diagnose gastroesophageal reflux disease in patients with noncardiac chest pain?: a meta-analysis. Arch Intern Med. 2005;165(11):1222-8. [pmid: 15956000].
716 Wang Y, Sun G, Pan JG, et al. Performance of tPSA and f/tPSA for prostate cancer in Chinese. A systematic review and meta-analysis. Prostate Cancer Prostatic Dis. 2006;9(4):374-8. [pmid: 16926855].
717 Wang ZP, Li H, Hao LZ, et al. The effectiveness of prenatal serum biomarker screening for neural tube defects in second trimester pregnant women: a meta-analysis. Prenat Diagn. 2009;29(10):960-5. [pmid: 19609892].
718 Wardlaw JM, Chappell FM, Best JJ, et al. Non-invasive imaging compared with intra-arterial angiography in the diagnosis of symptomatic carotid stenosis: a meta-analysis. Lancet. 2006;367(9521):1503-12. [pmid: 16679163].
719 Warner E, Messersmith H, Causer P, et al. Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. Ann Intern Med. 2008;148(9):671-9. [pmid: 18458280].
720 Watson EJ, Templeton A, Russell I, et al. The accuracy and efficacy of screening tests for Chlamydia trachomatis: a systematic review. J Med Microbiol. 2002;51(12):1021-31. [pmid: 12466399].
721 Weinschenker P, Soares HP, Clark O, et al. Immunocytochemical detection of epithelial cells in the bone marrow of primary breast cancer patients: a meta-analysis. Breast Cancer Res Treat. 2004;87(3):215-24. [pmid: 15528964].
722 Wellnitz U, Binder B, Fritz P, et al. Reliability of telepathology for frozen section service. Anal Cell Pathol. 2000;21(3-4):213-22. [pmid: 11339570].
723 Wells PS, Lensing AW, Davidson BL, et al. Accuracy of ultrasound for the diagnosis of deep venous thrombosis in asymptomatic patients after orthopedic surgery. A meta-analysis. Ann Intern Med. 1995;122(1):47-53. [pmid: 7985896].
724 West J, Goodacre S, Sampson F. The value of clinical features in the diagnosis of acute pulmonary embolism: systematic review and meta-analysis. QJM. 2007;100(12):763-9. [pmid: 18089542].
725 Westerterp M, van Westreenen HL, Reitsma JB, et al. Esophageal cancer: CT, endoscopic US, and FDG PET for assessment of response to neoadjuvant therapy—systematic review. Radiology. 2005;236(3):841-51. [pmid: 16118165].
726 Weston AR, Jackson TJ, Blamey S. Diagnosis of appendicitis in adults by ultrasonography or computed tomography: a systematic review and meta-analysis. Int J Technol Assess Health Care. 2005;21(3):368-79. [pmid: 16110717].
727 Westwood ME, Kelly S, Berry E, et al. Use of magnetic resonance angiography to select candidates with recently symptomatic carotid stenosis for surgery: systematic review. BMJ. 2002;324(7331):198. [pmid: 11809640].
728 Westwood ME, Whiting PF, Cooper J, et al. Further investigation of confirmed urinary tract infection (UTI) in children under five years: a systematic review. BMC Pediatr. 2005;5(1):2. [pmid: 15769296].
729 White PM, Wardlaw JM, Easton V. Can noninvasive imaging accurately depict intracranial aneurysms? A systematic review. Radiology. 2000;217(2):361-70. [pmid: 11058629].
730 White RH, McGahan JP, Daschbach MM, et al. Diagnosis of deep-vein thrombosis using duplex ultrasound. Ann Intern Med. 1989;111(4):297-304. [pmid: 2667418].
731 Whiting P, Harbord R, Main C, et al. Accuracy of magnetic resonance imaging for the diagnosis of multiple sclerosis: systematic review. BMJ. 2006;332(7546):875-84. [pmid: 16565096].
732 Whiting P, Westwood M, Watt I, et al. Rapid tests and urine sampling techniques for the diagnosis of urinary tract infection (UTI) in children under five years: a systematic review. BMC Pediatr. 2005;5(1):4. [pmid: 15811182].
733 Whitsel EA, Boyko EJ, Siscovick DS. Reassessing the role of QTc in the diagnosis of autonomic failure among patients with diabetes: a meta-analysis. Diabetes Care. 2000;23(2):241-7. [pmid: 10868838].
734 Wiering B, Krabbe PF, Jager GJ, et al. The impact of fluor-18-deoxyglucose-positron emission tomography in the management of colorectal liver metastases. Cancer. 2005;104(12):2658-70. [pmid: 16315241].
735 Wiese W, Patel SR, Patel SC, et al. A meta-analysis of the Papanicolaou smear and wet mount for the diagnosis of vaginal trichomoniasis. Am J Med. 2000;108(4):301-8. [pmid: 11014723].
736 Wijnberger LD, Huisjes AJ, Voorbij HA, et al. The accuracy of lamellar body count and lecithin/sphingomyelin ratio in the prediction of neonatal respiratory distress syndrome: a meta-analysis. BJOG. 2001;108(6):583-8. [pmid: 11426891].
737 Wilhelmus KR, Hassan SS. The prognostic role of donor corneoscleral rim cultures in corneal transplantation. Ophthalmology. 2007;114(3):440-5. [pmid: 17324694].
738 Will O, Purkayastha S, Chan C, et al. Diagnostic precision of nanoparticle-enhanced MRI for lymph-node metastases: a meta-analysis. Lancet Oncol. 2006;7(1):52-60. [pmid: 16389184].
739 Williams GJ, Macaskill P, Chan SF, et al. Comparative accuracy of renal duplex sonographic parameters in the diagnosis of renal artery stenosis: paired and unpaired analysis. AJR Am J Roentgenol. 2007;188(3):798-811. [pmid: 17312071].
740 Williams JW Jr, Noel PH, Cordes JA, et al. Is this patient clinically depressed?. JAMA. 2002;287(9):1160-70. [pmid: 11879114].
741 Willmann O, Wennberg R, May T, Woermann FG, Pohlmann-Eden B. The role of 1H magnetic resonance spectroscopy in pre-operative evaluation for epilepsy surgery. A meta-analysis. Epilepsy Res. 2006;71(2-3):149-58. [pmid: 16890408].
742 Willmann O, Wennberg R, May T, et al. The contribution of 18F-FDG PET in preoperative epilepsy surgery evaluation for patients with temporal lobe epilepsy A meta-analysis. Seizure. 2007;16(6):509-20. [pmid: 17532231].
743 Windeler J, Kobberling J. Colorectal carcinoma and Haemoccult. A study of its value in mass screening using meta-analysis. Int J Colorectal Dis. 1987;2(4):223-8. [pmid: 3320232].
744 Wittkampf KA, Naeije L, Schene AH, et al. Diagnostic accuracy of the mood module of the Patient Health Questionnaire: a systematic review. Gen Hosp Psychiatry. 2007;29(5):388-95. [pmid: 17888804].
745 Wiwanitkit V. Prostate specific antigen for screening for prostate cancer: an appraisal of Thai reports. Asian Pac J Cancer Prev. 2004;5(4):406-8. [pmid: 15546246].
746 Wolfer LR, Derby R, Lee JE, et al. Systematic review of lumbar provocation discography in asymptomatic subjects with a meta-analysis of false-positive rates. Pain Physician. 2008;11(4):513-38. [pmid: 18690280].
747 Worster A, Balion CM, Hill SA, et al. Diagnostic accuracy of BNP and NT-proBNP in patients presenting to acute care settings with dyspnea: a systematic review. Clin Biochem. 2008;41(4-5):250-9. [pmid: 17915204].
748 Worster A, Preyra I, Weaver B, et al. The accuracy of noncontrast helical computed tomography versus intravenous pyelography in the diagnosis of suspected acute urolithiasis: a meta-analysis. Ann Emerg Med. 2002;40(3):280-6. [pmid: 12192351].
749 Wu AH, Lane PL. Metaanalysis in clinical chemistry: validation of cardiac troponin T as a marker for ischemic heart diseases. Clin Chem. 1995;41(8 Pt 2):1228-33. [pmid: 7628112].
750 Wykes CB, Clark TJ, Khan KS. Accuracy of laparoscopy in the diagnosis of endometriosis: a systematic quantitative review. BJOG. 2004;111(11):1204-12. [pmid: 15521864].
751 Xing Y, Foy M, Cox DD, et al. Meta-analysis of sentinel lymph node biopsy after preoperative chemotherapy in patients with breast cancer. Br J Surg. 2006;93(5):539-46. [pmid: 16329089].
752 Yu SH, Kim CB, Park JW, et al. Ultrasonography in the diagnosis of appendicitis: evaluation by meta-analysis. Korean J Radiol. 2005;6(4):267-77. [pmid: 16374085].
753 Yuan W, Chen L, Bernal AL. Is elevated maternal serum alpha-fetoprotein in the second trimester of pregnancy associated with increased preterm birth risk? A systematic review and meta-analysis. Eur J Obstet Gynecol Reprod Biol. 2009;145(1):57-64. [pmid: 19457604].
754 Yuan Y, Gu ZX, Wei WS. Fluorodeoxyglucose-positron-emission tomography, single-photon emission tomography, and structural MR imaging for prediction of rapid conversion to Alzheimer disease in patients with mild cognitive impairment: a meta-analysis. AJNR Am J Neuroradiol. 2009;30(2):404-10. [pmid: 19001534].
755 Zandbergen EG, de Haan RJ, Stoutenbeek CP, et al. Systematic review of early prediction of poor outcome in anoxic-ischaemic coma. Lancet. 1998;352(9143):1808-12. [pmid: 9851380].
756 Zhang C, Chen Y, Xue H, et al. Diagnostic value of FDG-PET in recurrent colorectal carcinoma: a meta-analysis. Int J Cancer. 2009;124(1):167-73. [pmid: 18844237].
757 Zhao WY, Luo M, Sun YW, et al. Computed tomography in diagnosing vascular invasion in pancreatic and periampullary cancers: a systematic review and meta-analysis. Hepatobiliary Pancreat Dis Int. 2009;8(5):457-64. [pmid: 19822487].
758 Zielinski GD, Bais AG, Helmerhorst TJ, et al. HPV testing and monitoring of women after treatment of CIN 3: review of the literature and meta-analysis. Obstet Gynecol Surv. 2004;59(7):543-53. [pmid: 15199273].
759 Zijlstra JM, Lindauer-van der Werf G, Hoekstra OS, et al. 18F-fluoro-deoxyglucose positron emission tomography for post-treatment evaluation of malignant lymphoma: a systematic review. Haematologica. 2006;91(4):522-9. [pmid: 16585017].
760 Zintzaras E, Germenis AE. Performance of antibodies against tissue transglutaminase for the diagnosis of celiac disease: meta-analysis. Clin Vaccine Immunol. 2006;13(2):187-92. [pmid: 16467324].