# Search Strategy

Ovid MEDLINE (1966-2009)

1. exp “sensitivity and specificity”/
2. exp Predictive Value of Tests/
3. exp ROC CURVE/
4. exp Mass Screening/
5. exp diagnosis/
6. exp REPRODUCIBILITY OF RESULTS/
7. exp false negative reactions/ or false positive reactions.mp.
8. predictive value.tw.
9. (sensitivity or specificity).tw.
10. accuracy.tw.
11. screening.tw.
12. roc.tw.
13. reproducibility.tw.
14. (false positive or false negative).tw.
15. likelihood ratio.tw.
16. accuracy.tw.
17. di.fs.
18. or/1-17
19. limit 18 to meta analysis
20. systematic review$.tw.
21. meta analy$.tw.
22. 20 or 21
23. exp Meta-Analysis/
24. 18 and 23
25. 18 and 22
26. 19 or 24 or 25
27. limit 26 to human
28. limit 27 to english language