# Appendixes

Appendix A Search Strategy

Appendix B Data Extraction Form

Appendix C List of Included Studies

Appendix D Reasons for Exclusion

Appendix E Regression Analyses for Trends Over Time

Appendix F Regression Analyses for Citation Count and Journal Impact Factor