# Abbreviations

ANOVA: analysis of variance
AHRQ: Agency for Healthcare Research and Quality
CI: confidence interval
EPC: Evidence-based Practice Center
OR: odds ratio
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
QUOROM: Quality of Reporting of Meta-analyses
ROC: receiver operating characteristic
STARD: STAndards for the Reporting of Diagnostic Accuracy Studies