# Results

Our search for final reports of CERs on the Effective Health Care Program Web site yielded 129 records. Of the 129 reports, we identified 88 eligible CERs (76 of a therapeutic intervention, 12 of a preventive intervention). From the eligible CERs, we initially selected a sample of 25 percent of the most recently published CERs to review (n=20 therapeutic, n=3 preventive). A list of the CERs included in our study is available in Appendix B. Table 1 provides an overview of the characteristics of the CERs.

Table 1 Characteristics of included comparative effectiveness reviews

CER Number, Author, Date, EPC | Condition and Intervention | Observational Studies | Included Studies | Observational Study QA, Analysis, and SOE | Eligible SOE Comparisons^*^
76: Chou R et al., Nov 2012, Oregon | Infectious Disease: Hepatitis C Therapeutic Pharmaceutical | Not eligible | — | — | No
82: Maglione MA et al., Jun 2013, Southern California | Obesity Therapeutic Pharmaceutical, Surgical, Behavioral/educational | All observational study designs with >3 patients eligible | 4 trials 20 observational (10 cohort, 1 CC, 9 CS) | NR Narrative description Graded separately, then combined with trials | Yes
88: Penson DF et al., Dec 2012, Vanderbilt | Genitourinary: Cryptorchidism Therapeutic Pharmaceutical, Surgical | All observational studies excluding CRs | 16 trials 24 observational (3 PCS, 21 RCS) | Newcastle-Ottawa Scale MA, Narrative description Graded separately, then combined with trials | Yes
89: Goldman FJ et al., Apr 2013, North Carolina | Mental Health: Trauma Therapeutic Pharmaceutical, Behavioral/educational | All observational study designs with >10 patients eligible | 24 trials 1 cohort | EPC generated tool with items specific to study design Narrative description, studies with high ROB excluded from results Graded separately, then combined with trials | No
90: Saha S et al., May 2013, Oregon | Functional Limitations: Pressure Ulcers Therapeutic Pharmaceutical, Surgical, Procedural, Device/equipment | Different observational designs eligible based on available level of evidence per KQ | 143 trials 31 observational (1 PCS, 2 RCS, 2 cohort NOS, 1 before-after, 7 CS, 18 NR) | EPC generated tool based on Downs and Black Narrative description Graded together with trials | Yes
91: Sun X et al., Dec 2012, Oregon | Infectious Disease: Hepatitis C Therapeutic Pharmaceutical, Tx adherence, Management of AEs | All study designs eligible | 6 trials 6 observational (3 PCS, 3 RCS) | Newcastle-Ottawa Scale Narrative description Graded together with trials | Yes
92: Jonas DE et al., Apr 2013, RTI–UNC | Mental Health: Posttraumatic stress disorder Therapeutic Pharmaceutical, Behavioral/educational | Observational studies excluded for KQ 1–5, included for KQ6 with sample size >500 | 92 trials 0 observational | – | No
93: Belinson S et al., Dec 2012, Blue Cross | Cancer: Colorectal Cancer Therapeutic Pharmaceutical, Surgical, Procedural | All study designs eligible | 0 trials (1 RCT included, but treated as a CS) 30 CS (13 prospective, 17 retrospective) | Carey and Boden criteria Narrative description Graded separately, then combined with trials | No
94: Ferluga ED et al., Mar 2013, Vanderbilt | Brain or Nerve Condition: Cerebral Palsy Therapeutic Surgical, Behavioral/educational, Nutritional interventions | All study designs eligible except CRs as long as before-after data provided | 1 trial 11 observational (1 PCS, 10 CS) | Newcastle-Ottawa Scale, AHRQ methods guide approach Narrative description Graded together with trials | Yes
96: Hartmann KE et al., Mar 2013, Vanderbilt | Gynecology: Abnormal Uterine Bleeding Therapeutic Pharmaceutical, Behavioral/educational, Device, CAM | All study designs eligible | 0 trials 25 observational (cohort, CC, post-marketing surveillance studies, registry data (N not specified)) | QA method not specified Narrative description – | No
100: McCrory DC et al., Jan 2013, Duke | Airway Condition: Chronic Cough Therapeutic Pharmaceutical, Behavioral/educational, CAM | RCTs and cohort studies eligible | 45 trials 3 cohorts | AHRQ methods guide approach – – | No
101: Berkman ND et al., May 2013, RTI–UNC | ENT: Otitis Media with Effusion Therapeutic Pharmaceutical, Surgical, Procedural, CAM | Trials and observational studies eligible (PCS, RCS, CC only) | 55 trials 4 observational (3 RCS, 1 not specified) | Modified Cochrane ROB tool Narrative description, studies with high ROB included only for harms Graded together with trials | Yes
107: Forman-Hoffman V et al., Feb 2013, RTI–UNC | Mental Health: Trauma Therapeutic Pharmaceutical, Behavioral/educational, CAM | All study designs eligible, studies with high ROB excluded | 21 trials 1 PCS | Cochrane ROB tool, AHRQ criteria, RTI item bank Narrative description Graded separately, then combined with trials | No
108: Shamliyan TA et al., Jun 2013, Minnesota | Brain or Nerve Condition: Migraine Prevention Pharmaceutical, Non-pharmaceutical | Eligible study designs not specified | 26 trials 16 other (4 retrospective reviews, 2 prospective reviews,1 chart review, 1 CS, 8 unspecified) | RTI item bank Narrative description SOE methods unclear, study designs maybe combined | Yes
111: Lin SY et al., Mar 2013, Johns Hopkins | Airway Condition: Allergic Rhinoconjunctivits, Asthma Therapeutic Allergen-specific immunotherapy | Not eligible | – | – | No
112: Ratko TA et al., Jun 2013, Blue Cross | Cancer: Lung Cancer Therapeutic Procedure | All study designs eligible | 5 trials 50 observational (single arm studies [15 prospective, 21 retrospective, 13 not specified], 1 retrospective nonrandomized comparative study) | Carey and Boden criteria Narrative description Graded separately, then combined with trials | No
113: Grant MD et al., Apr 2013, Blue Cross | Cancer: Anemia Therapeutic Pharmaceutical | Comparative observational studies >250 patients for KQ1 | 54 trials 0 observational | –
114: Belinson S et al., May 2013, Blue Cross | Cancer: Hepatocellular Carcinoma Therapeutic Procedure | All study designs eligible, CRs included only for KQ on harms | 6 trials 42 observational (1 PCS, 4 RCS, 2 CC, 32 CS, 3 CRs) | USPSTF for RCTs and nonrandomized comparative studies, Carey and Boden criteria for single-arm studies Narrative description Graded together with trials
115: Wang Y et al., Jun 2013, Johns Hopkins | Obesity: Childhood Obesity Prevention Behavioral/educational, Community-based intervention | Not eligible | – | –
116: Singh S et al., May 2013, Johns Hopkins | Heart and Blood Vessel Condition: Venous Thromboembolism Prevention Pharmaceutical, Mechanical | All study designs eligible | 6 trials 95 observational (16 PCS, 24 RCS, 6 CS, 8 CRs, 37 uncontrolled cohort, 4 not specified) | Downs and Black MA included both trials and OS, Narrative description Graded together with trials
117: McCrory DC et al., Apr 2013, Duke | Heart and Blood Vessel Condition: Pulmonary Arterial Hypertension Therapeutic Pharmaceutical | Prospective, retrospective studies, registry data eligible for KQ3 only | 28 trials 9 observational (4 retrospective CS, 5 prospective CS) | Cochrane ROB tool – SOE method unclear
118: Jones WS et al., May 2013, Duke | Heart and Blood Vessel Condition: Peripheral Artery Disease Therapeutic Pharmaceutical, Surgical, Procedural, Behavioral/education | PCS, RCS eligible | 40 trials 43 observational (3 PCS, 1 PCS, 39 unclear) | EPC methods guide MA included both trials and OS, Narrative description Graded together with trials | Yes
119: Al-Khatib SM et al., Jun 2013, Duke | Heart and Blood Vessel Condition: Atrial Fibrillation Therapeutic Pharmaceutical, Procedural | Prospective, retrospective studies, registries >100 patients | 146 trials 2 observational (not specified) | Modified AHRQ methods guide Narrative description SOE method unclear | Yes

Notes: AEs = adverse events; CAM = complementary and alternative medicine; CC = case control; CER = comparative effectiveness review; CS = case series; CR = case report; KQ = Key Question; MA = meta-analysis; N = number; NOS = not otherwise specified; NR = not reported; PCS = prospective cohort study; QA = quality assessment; RCS = retrospective cohort study; RCT = randomized controlled trial; ROB = risk of bias; SOE = strength of evidence; Tx = treatment

* Comparison must be graded and have data from at least 1 trial and 1 observational study

The 23 CERs were conducted across nine EPCs and published between November 2012 and June 2013. They focused on a range of health condition categories: brain or nerve (n=2), breathing (n=2), cancer (n=4), eye, ear or throat (n=1), physical disabilities (n=1), genitourinary (n=1), gynecology (n=1), heart and blood vessel (n=4), infectious disease (n=2), mental health (n=3), and obesity (n=2). The majority of the CERs examined pharmaceutical interventions (n=18), either alongside other types of nonpharmaceutical interventions (n=15) or as the only intervention category (n=3). Surgical (n=7), procedural (n=7), and behavioral or educational (n=9) interventions were also commonly examined.

The reviewers from the EPCs searched for observational studies in 20 CERs (87 percent), including 2 of the 3 preventive CERs. Only seven CERs (30 percent) provided a rationale for their decision to include or exclude observational studies. Common reasons cited to justify including observational studies were to provide additional data for adverse events (n=4), a limited number of trials (n=1), and to target special populations that are typically excluded from trials (n=1). Reasons given to justify excluding observational studies were the methodological limitations of observational studies (n=2) and a sufficient number of trials available (n=1).

The observational study designs that were most often considered eligible were prospective or retrospective cohort studies (n=20) and case control studies (n=9). Case series and case reports were eligible in four reviews. Several CERs considered all observational studies to be eligible (n=4) or excluded only case reports (n=4). Three CERs used a hierarchy of evidence approach, such as including noncomparative observational studies only if comparative observational studies were not identified.

Half of the CERs (n=11) used different study design criteria for different Key Questions. Some reviewers decided a priori that it would be inappropriate to base decisions about effectiveness on observational studies, and therefore excluded these studies from Key Questions that focused on clinical benefit.10 Overall, observational studies were eligible for inclusion in 68 percent of the Key Questions examining only clinical benefits, 73 percent of Key Questions examining both clinical benefits and harms, and 85 percent of Key Questions examining only harms.

A median of 11 observational studies (interquartile range: 2, 31) were included in the 20 CERs that searched for observational studies. Two CERs intended to include observational studies, but found no studies to meet their eligibility criteria.10,11 The total number of included observational studies was unclear in three CERs. Table 1 provides the number of observational studies included in each CER by study design. Overall, the CERs predominantly included cohort studies and case series. In some reviews, study designs were difficult to categorize due to ambiguity of terms, such as “retrospective review,” “nonrandomized comparative study,” and “uncontrolled cohort.” Occasionally, the distribution of study designs could not be determined because all studies were described simply as “trials” or “observational.” Some CERs used study design algorithms, such as the taxonomy developed by the Alberta EPC, to categorize the included studies.12,13

A wide range of approaches were used to assess the quality of observational studies. The quality assessment tools included the Newcastle-Ottawa Scale (n=3), Cochrane Risk of Bias tool (n=3), Carey and Boden (n=2), Downs and Black scale (n=1), and the United States Preventive Services Task Force (USPSTF) tool (n=1). Some CERs reported rating quality items identified by the EPC (n=4) or stated that the approach to quality assessment was based on the EPC methods guide (n=6). Four CERs reported using different quality assessment tools for different observational study designs. In six CERs, a quality threshold was used to determine which observational studies would contribute data to the review.10,12-16 For example, some reviews excluded studies rated to be at high risk of bias from the results or SOE assessment.13,14

The majority of the CERs provided a narrative description of the results of observational studies (n=16). Observational studies were included in a meta-analysis in three CERs;17-19 in two, the data from observational studies were pooled with trial data.17,19 One CER plotted the results of observational studies on a graph without conducting a meta-analysis.19

Of the 18 CERs that included observational studies, 16 incorporated observational studies in grading the SOE. Only seven CERs provided some description of the methods used to grade the observational studies.18-24 Evidence from observational studies was graded together with trials in seven CERs and separately from trials in six; in three CERs it was unclear whether SOE was graded separately or together with trials. Observational studies were not included in the SOE assessments in two CERs.

We identified 78 comparisons from 12 CERs for which both trials and observational studies provided evidence and whose outcomes were graded. Observational studies had an impact on the SOE assessments for 19 comparisons (24 percent), had no impact for 37 comparisons (47 percent), and had an unclear impact for 22 comparisons (28 percent). Similarly, observational studies were assessed to have had an impact on the conclusions of the CER for 18 comparisons (23 percent), no impact for 39 comparisons (50 percent), and an unclear impact for 21 comparisons (27 percent).

We conducted subgroup analyses to determine whether the impact of observational studies on SOE assessments and conclusions was related to various characteristics of the CERs. Our subgroup analyses were limited by the small number of CERs (n=12) that provided data. Four CERs examined heart and blood vessel conditions, two examined brain and nerve conditions, and the remaining six CERs each examined a different health condition. Observational studies had an effect on the SOE in 35 percent of the comparisons on heart and blood vessel CER topics compared with 15 percent of all other CER health topics combined. Similarly, observational studies appeared to have a greater impact in comparisons that examined a surgical intervention (31 percent; n=26 comparisons) and devices (33 percent; n=9 comparisons) than for pharmaceuticals (11 percent; n=18 comparisons). For CERs that only included comparative observational designs (i.e., cohort or case control studies), observational studies were more likely to have an impact on SOE assessments (46 percent; n=26 comparisons) compared with CERs that included comparative and uncontrolled designs (17 percent; n=42 comparisons).

We re-ran the Medline or PubMed searches for a sample of five CERs both without a study design filter and with the Cochrane RCT filter applied. Appendix C provides a summary table of the findings. On average, applying an RCT filter reduced the search yield by 65 percent or 2,031 records. Using an estimated average screening rate of 100 records per hour, an RCT filter may reduce screening time by approximately 20 hours. The yield reduction varied considerably across CERs, ranging from a 39 percent reduction to a 92 percent reduction, depending on the initial search strategy developed by the EPC.