# References

1 Higgins J, Green S, editors. Cochrane handbook for systematic reviews of interventions Version 5.1.0. [updated March 2011]. 2011.
2 Moja L, Telaro E, D'Amico R, et al. Assessment of methodological quality of primary studies by systematic reviews: results of the metaquality cross sectional study. BMJ. 2005;330:1053-7. [pmid: 15817526].
3 Norris S, Atkins D. Challenges in using nonrandomized studies in systematic reviews of treatment interventions. Ann Intern Med. 2005;142:1112-9. [pmid: 15968036].
4 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: Assessing harms when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
5 Vandenbroucke J. When are observational studies as credible as randomised trials?. Lancet. 2004;363:1728-31. [pmid: 15158638].
6 Institute of Medicine. Finding what works in health care: Standards for systematic reviews. Washington, D.C. Institute of Medicine. 2011.
7 The GRADE Working Group. GRADE guidelines: 9. Rating up the quality of evidence. J Clin Epidemiol. 2011;64:1311-6. [pmid: 21802902].
8 Norris S, Atkins D, Bruening W, et al. Observational studies in systemic reviews of comparative effectiveness: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1178-86. [pmid: 21636246].
9 Hartling L, Bond K, Harvey K, et al. Developing and testing a tool for the classification of study designs in systematic reviews of interventions and exposures: methods research report. AHRQ Publication No. 11-EHC-007. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
10 Jonas DE, Cusack K, Forneris CA, et al. Psychological and Pharmacological Treatments for Adults With Posttraumatic Stress Disorder (PTSD). Comparative Effectiveness Review No. 92. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 13-EHC011-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013.
11 Grant MD, Piper M, Bohlius J, et al. Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment: Comparative Effectiveness Update. Comparative Effectiveness Review No. 113. (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 13-EHC077-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013.
12 Goldman Fraser J, Lloyd SW, Murphy RA, et al. Child Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Maltreatment. Comparative Effectiveness Review No. 89. (Prepared by the RTIUNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 13-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013.
13 Forman-Hoffman V, Knauer S, McKeeman J, et al. Child and Adolescent Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Trauma Other Than Maltreatment or Family Violence. Comparative Effectiveness Review No. F. (Prepared by the RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 13-EHC054-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2013.
14 Berkman ND, Wallace IF, Steiner MJ, et al. Otitis Media With Effusion: Comparative Effectiveness of Treatments. Comparative Effectiveness Review No. 101. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 13-EHC091-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013.
15 Hartmann KE, Jerome RN, Lindegren ML, et al. Primary Care Management of Abnormal Uterine Bleeding. Comparative Effectiveness Review No. 96. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065 I.) AHRQ Publication No. 13-EHC025-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2013.
16 Saha S, Smith MEB, Totten A, et al. Pressure Ulcer Treatment Strategies: Comparative Effectiveness. Comparative Effectiveness Review No. 90. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 13-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013.
17 Jones WS, Schmit KM, Vemulapalli S, et al. Treatment Strategies for Patients With Peripheral Artery Disease. Comparative Effectiveness Review No. 118. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 13-EHC090-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013.
18 Penson DF, Krishnaswami S, Jules A, et al. Evaluation and Treatment of Cryptorchidism. Comparative Effectiveness Review No. 88. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 13-EHC001-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2012.
19 Singh S, Haut ER, Brotman DJ, et al. Pharmacologic and Mechanical Prophylaxis of Venous Thromboembolism Among Special Populations. Comparative Effectiveness Review No. 116. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13-EHC082-1. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013.
20 Al-Khatib SM, Allen Lapointe N, Chatterjee R, et al. Treatment of Atrial Fibrillation. Comparative Effectiveness Review 119. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 13-EHC095-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2013.
21 Belinson S, Chopra R, Yang Y, et al. Local Hepatic Therapies for Metastases to the Liver From Unresectable Colorectal Cancer. Comparative Effectiveness Review No. 93. (Prepared by Blue Cross and Blue Cross Blue Shield Association Technology Evaluation Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 13-EHC014-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2012.
22 Belinson S, Yang Y, Chopra R, et al. Local Therapies for Unresectable Primary Hepatocellular Carcinoma. Comparative Effectiveness Review No. 114. (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 13-EHC069-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013.
23 Ratko TA, Vats V, Brock J, et al. Local Nonsurgical Therapies for Stage I and Symptomatic Obstructive Non–Small-Cell Lung Cancer. Comparative Effectiveness Review No. 112. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 13-EHC071-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2013.
24 Shamliyan TA, Kane RL, Ramakrishnan R, et al. Migraine in Children: Preventive Pharmacologic Treatments. Comparative Effectiveness Review No. 108. (Prepared by the University of Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 13-EHC065-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2013.
25 Berkman ND, Wallace IF, Steiner MJ, et al. Otitis Media With Effusion: Comparative Effectiveness of Treatments. Comparative Effectiveness Review No. 101. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 13-EHC091-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013.