# Methods

We conducted a study of a sample of recently published CERs that have been conducted within the EPC program. To identify CERs, we searched the Effective Health Care Program Web site for all final reports of research reviews published in English. The search was conducted in June 2013. A single reviewer screened the titles, abstracts, and Key Questions of these reviews by applying predefined inclusion criteria. In order to be eligible for our study, the review was required to be the final report of a CER and have at least one Key Question that: (a) examined a therapeutic or preventive intervention (i.e., screening and diagnostic reviews were excluded); and (b) provided an intervention at an individual-patient level (i.e., program or health systems interventions were excluded). We selected a 25 percent sample of the eligible CERs, based on most recent date of publication, due to time constraints. The most recent CERs were selected because they are more representative of current EPC practices, particularly with respect to SOE assessments.

The data extraction form is available in Appendix A. Data were extracted by one reviewer using a standard form and verified by a second reviewer. Discrepancies were resolved by discussion or third-party arbitration.

First, we extracted descriptive data from each CER, including the clinical area, type of intervention (e.g., drug, surgery, nonpharmacological), year of publication, total number of studies included, and the number and types of Key Questions (e.g., clinical benefit, adverse events). We extracted information on whether or not the reviewers intended to include observational studies; the rationale provided for the decision to include or exclude observational studies (e.g., long-term followup, safety outcomes, a priori impression that there are few RCTs on a topic); and the types of observational studies eligible for inclusion in the CER.

We defined observational studies as any nonexperimental design in which the investigators did not assign group exposure. Observational studies could be prospective or retrospective in their design or analysis, and could have a concurrent, historical, or within-group comparison or no comparison group. Common observational designs include cohort, case-control, before-after, cross-sectional, case series, and case report studies. As there is variability in the terminology used to describe study designs, we used the classification system developed by the Alberta EPC.9

For Key Questions that included observational studies, we extracted the number and type of study designs included, the tools used to assess study quality, and the approaches used to present study findings. Specifically, we extracted information on whether the observational data were analyzed quantitatively in a meta-analysis (either separately or together with trials), qualitatively (e.g., narrative description of findings), or displayed graphically in a visual analysis. We looked for examples of CERs that presented data in particularly effective ways in order to generate ideas on novel approaches to summarizing findings from observational studies. We recorded whether observational studies were included in the SOE assessments and any specific methods described for grading observational studies (e.g., additional domains assessed, how assessments for observational studies were combined with those for trials).

For outcomes that were graded, we identified all comparisons for which both trials and observational studies provided data. We focused on these comparisons due to resource limitations. Using the SOE tables, we assessed whether observational studies appeared to have an impact on the individual domains (risk of bias, consistency, directness, and precision) and on the overall SOE assessments. We rated whether observational studies had an impact on SOE as “yes,” “no,” or “unclear” for each comparison and outcome. When SOE tables were not available in the report or appendixes, or the number of studies and the designs that contributed to each comparison and outcome were not reported, we rated the impact of observational studies as “unclear.” The assessments were made by one reviewer and verified by a second reviewer. For each comparison and outcome, we recorded comments justifying our assessments.

We developed principles to guide our assessments of the impact of observational studies through an iterative process and discussions about the various scenarios encountered. For each outcome, we considered the proportion of studies and patients contributed by observational studies versus trials; the quality of the observational studies compared with the trials; whether the findings from observational studies were consistent with those of the trials; whether there were differences in the directness of the comparisons or outcomes between observational studies and trials; and whether precision appeared to be affected by the inclusion of observational studies. When more than one trial reported on a given outcome, we assessed that the impact of observational studies was minimal unless the findings were discordant with those observed in the trials. When the overall SOE was rated insufficient, we generally assessed that the observational studies had made no contribution to the SOE unless it was apparent that the addition of observational studies lowered the SOE in one or more domains.

We engaged in a similar iterative process to evaluate the impact of observational studies on CER conclusions. When observational studies were evaluated to have no impact on SOE, we rated that they also did not affect the conclusions unless the conclusions incorporated the balance between benefits and harms and observational studies contributed to the harms evidence. When the conclusions reiterated the SOE rating, then we provided the same rating across both categories. We considered conclusions reported in the abstract, executive summary, and the discussion section of the CER because we found that sometimes different outcomes were included or different wording was used within individual reports. Further, we conducted subgroup analyses to examine whether any characteristics of the CERs (e.g., health condition, intervention type, types of observational studies included) were associated with a more likely impact of observational studies on SOE assessments.

Finally, we re-ran the Medline or PubMed search strategies with and without a Cochrane RCT filter for a sample of five CERs conducted by different EPCs across a variety of topics. We compared the yield of records identified through the two searches to estimate the added time and human resources involved in including observational studies alongside trials in a CER.