# Introduction

Historically, systematic reviews of health care interventions have focused primarily on randomized controlled trials (RCTs) because they are more likely to provide unbiased data about the differential effects of treatment options than other study designs.1 Because randomization controls for both known and unknown confounders, differences between the study groups of RCTs can be attributed to the intervention of interest. However, for some interventions, randomization may not be considered ethical or feasible. In addition, trials may provide inadequate data on harms due to short followup periods or have limited applicability to real-world settings. For some comparisons of interest, evidence from RCTs may be sparse or unavailable.

Systematic reviewers are increasingly considering evidence from observational studies to address gaps in the RCT evidence.2,3 Observational studies may provide longer followup data, be conducted in settings that more closely resemble clinical practice, report on rare outcomes, and provide evidence for interventions that cannot be randomized.1 Although there is general consensus that observational studies, especially those based on large clinical or administrative databases, provide a valuable contribution for assessing potential harms, the role of observational studies in addressing questions of clinical benefit is much disputed.4 Concerns about the risks of bias inherent to nonexperimental studies, particularly due to baseline differences between the intervention groups, are often cited as reasons to exclude observational studies from systematic reviews.1,5 Furthermore, the inclusion of observational studies may also add significant time and resource requirements to the review process.

Several organizations have provided guidance on when to consider including observational studies in systematic reviews. In their Standards for Systematic Reviews, the Institute of Medicine recommends that observational studies be used in addition to RCTs to evaluate harms of interventions and be considered to address gaps in the evidence from RCTs on the benefits of interventions.6 The Cochrane Handbook stipulates that the inclusion of nonrandomized studies may be justified to provide: (a) an evaluation of their methodological weaknesses in the context of building a case for the need for RCTs; (b) evidence of the effects of interventions that cannot be randomized; and c) evidence of effects that cannot be adequately examined in RCTs.1 Similarly, guidance from the Grading of Recommendations Assessment, Development and Evaluation Working Group suggests that observational studies may be used to complement data from trials or when no trials are available.7

The Agency for Healthcare Research and Quality (AHRQ) recently developed a conceptual framework for considering the inclusion of observational studies in comparative effectiveness reviews (CERs) of therapeutic interventions.8 For CERs, which compare the relative benefits and harms among a range of available interventions for a given condition, reviewers are cautioned against developing protocols that rule out the inclusion of observational studies a priori. RCTs are thought to often be insufficient to address all aspects of CER research questions.8 Guidelines for deciding whether or not to use evidence from observational studies include whether gaps exist in the evidence from RCTs and whether observational studies provide useful and valid information.8

Despite guidance that supports considering observational studies for inclusion in systematic reviews, there is a lack of empirical evidence to demonstrate the impact observational studies have on their findings, strength of evidence (SOE) assessments, and conclusions. Because the inclusion of observational studies involves additional workload and may increase resource requirements and timelines, it is important to understand when and in what context (e.g., different topics, clinical areas) observational studies are likely to provide additional evidence and strengthen the conclusions of a CER. An Evidence-based Practice Center (EPC) Working Group is concurrently preparing a white paper that presents case examples of when observational studies were used in evidence reviews of therapeutic interventions and how they contributed to the overall evidence synthesis. Our methods report expands on this work by generating empirical evidence of the impact observational studies have on the results and conclusions of CERs from the EPC program.

Our objectives were to systematically review CERs of therapeutic and preventive intervention to identify: (1) how often observational studies are searched for and included; (2) the rationale for including or excluding observational studies; (3) how data from observational studies are assessed for validity, presented, analyzed, and incorporated in the SOE assessments and conclusions; and (4) the impact or contribution of observational studies on the results, SOE, and overall conclusions.