# Discussion

In our sample of 23 CERs—all published since November 2012—EPCs searched for observational studies in 20, of which 18 included observational studies. A median of 11 (interquartile range: 2, 31) observational studies were included. Of these 18 CERs, 16 incorporated the observational studies in their SOE assessments. We identified 78 comparisons from 12 CERs for which both trials and observational studies provided evidence. We determined that observational studies had an impact on SOE and conclusions for 19 (24 percent) of the comparisons.

We found considerable diversity across the CERs regarding: decisions to include or exclude observational studies; the observational study designs that were considered; and, whether to specify study designs a priori or use a step-wise approach. The rationale for decisions was rarely provided. Further, there was diversity across the CERs in the approaches used to appraise, synthesize, and grade the SOE of observational studies.

The terminology used for observational study designs was inconsistent not only across CERs, but also within individual reports. It was sometimes difficult to determine what features were meant by certain labels. For example, a “controlled comparative study” could refer to a controlled clinical trial (nonrandomized) or a prospective cohort study. In some CERs specific study designs were not reported and studies were simply described as “observational” or “nonrandomized.” The terms “observational” and “nonrandomized” were sometimes used interchangeably although it was unclear whether controlled clinical trials or quasi-experimental study designs were considered for inclusion. By virtue of the study design, we may have more confidence in the results from a nonrandomized controlled trial than from a cohort study.

The quality of observational studies was assessed using a range of approaches and tools. Some EPCs used one tool across all study designs (e.g., USPSTF tool), while others used design-specific tools such as the Newcastle-Ottawa Scale for cohort studies. When observational studies were included in SOE assessments, it was not always clear how EPCs made decisions regarding the risk of bias domain when different quality assessment or risk of bias tools were used. It is challenging to derive an overall risk of bias assessment when different study designs are included and when different tools are used. For example, when there are two RCTs at high risk of bias and two cohort studies that are low risk of bias, what is the risk of bias for this cluster of studies that provide evidence for a specific outcome?

In assessing the SOE, some SOE tables did not indicate how many studies and which study designs contributed to the assessment. In some instances the numbers reported in the SOE table and the text of the CER did not match. This made it difficult to determine the impact of observational studies on the SOE and conclusions presented in the CERs.

For some CERs the SOE was graded separately for trials and observational studies, while others combined study designs. Where study designs were graded separately it was difficult to determine an overall SOE for an outcome. However, when the evidence for a comparison consists of several RCTs at low risk of bias and observational studies at high risk of bias, it may be appropriate to focus on the SOE assessment of trials alone and not combine study designs.

## Next Steps

In light of the observed diversity in the inclusion and reporting of observational studies, we feel that reporting guidelines and methods guidance are warranted in order to better ensure clarity and consistency across CERs.

### Reporting Guidelines

1. Clear reporting of the rationale for including or excluding observational studies for each Key Question;
2. Clear reporting of the type of observational studies that are considered for inclusion;
3. Consistent use of study design nomenclature (e.g., the Alberta EPC system) or study design features (e.g., the Cochrane Collaboration);
4. Clear reporting regarding how nonrandomized trials and observational studies are assessed for quality, analyzed, and graded;
5. Clear reporting of the number of studies of which designs are included in the CER;
6. Clear reporting of the number and designs of studies contributing evidence for comparisons on SOE tables.

### Methods Guidance

The recent AHRQ report on grading the SOE25 will clarify some issues regarding how to incorporate observational studies. However, there is still little guidance on how to combine the assessment of experimental and observational studies, and its absence will likely result in inconsistency across EPCs. The following are important questions that we believe need to be addressed through methods guidance.

1. When should observational studies be included in CERs and in SOE assessments?
2. Is there a hierarchy of study designs to consider when moving beyond RCTs?
3. Is it appropriate to set a sample size limit for observational studies (i.e., >1,000 patients, >10 patients)?
4. How do we assess risk of bias domain for SOE when different study designs use different tools?
5. What proportion of studies must be low risk of bias to give an overall score of “low”?
6. In what situations can observational studies affect SOE (either to raise or lower an assessment)?
7. How do we assess precision when observational studies are not combined in a meta-analysis?
8. How do we assess publication bias for observational studies?

## Limitations

It was challenging to determine what the impact of observational studies was on the SOE or conclusions. It was difficult to decide which conclusions to evaluate since the conclusions often reiterated the SOE assessments. Rarely did CERs present a conclusion that combined the balance of benefits and harms (e.g., benefit is good but the risk of harms from observational studies is sufficient to temper conclusions). Finally the subgroup analyses are based on a small sample size. While the subgroups were specified a priori, the results should still be considered as hypothesis-generating.