# Summary and Conclusion

In this paper, we examined a sample of 23 recent CERs to explore how observational studies contribute to the results and conclusions of CERs. We found considerable diversity across the CERs regarding decisions to include observational studies and the specific study designs that were considered. The rationale for decisions was rarely provided. We also observed variability in the approaches used to appraise, synthesize, and grade the SOE of observational studies.

It was not always clear that the inclusion of observational studies added value to the additional resources needed to search for, select, appraise, and analyze such studies. Reporting guidelines and methods guidance relating to observational studies is needed in order to ensure clarity and consistency in how observational studies are handled within the EPC Program.