# Search Yields With and Without an RCT Filter

Below is a summary of the search yields both with and without applying an RCT filter for a sample of five CERs.

Summary of Results

Search | Description | Results
(1) Non–Small-Cell Lung Cancer | Original search (without RCT filter) Filtered search (Cochrane RCT filter applied) | 3,386 1,121
(2) Migraine in Children | Original search (without RCT filter) Filtered search (Cochrane RCT filter applied) | 680 319
(3) Pressure Ulcers | Original search (without RCT filter) Filtered search (Cochrane RCT filter applied) | 5,038 424
(4) Otitis Media With Effusion | Original search (without SD filters) Search results (with original SD filters) Filtered search (Cochrane RCT filter applied) | 7,252 3,170 882
(5) Body Mass Index of 30.0 to 34.9 kg/m^2^ | Original search (without SD filters) Search results (with original SD filters) Filtered search (Cochrane RCT filter applied) | 5,047 1,628 999