# Results

## Registry Search Yield

Our initial search yield identified 6826 unique records (5085 in ClinicalTrials.gov, 1741 in ICTRP), (See Figure 1). After initial exclusion criteria were applied, 297 unique records were added to the evidence map and further assessed based on evaluation of basic population, intervention, outcome, study design, sample size criteria, and whether results were reported. At this juncture, 221 studies were excluded in the second round of screening, based on outcome-specific criteria defined in the report, most frequently because the study size was too small (43%; n=94) for the design (<30/arm in randomized controlled trials [RCTs] or <20 in crossover studies [XO]), the intervention/exposure was not specifically an n-3 FA (25%; n=54), or because the study did not evaluate a population of interest (9%; n=19). A full list of the excluded records and the reasons for exclusion is in Appendix D. A few studies had multiple registry records; one in ClinicalTrials.gov and a second in a national registry of another country listed in the ICTRP.

Figure 1 Literature flow

RCT: randomized controlled trial; XO crossover study; CT.gov: ClinicalTrials.gov; ICTRP: International Clinical Trials Registry Platform; CVD: cardiovascular disease; NRCS: non-randomized comparative study.

Figure 1 shows the literature flow for studies and records in the review. Overall, the searches identified 6826 unique records, of which 69 studies in 76 records were deemed relevant. The original report included 98 studies of which 26 were matched to records, 4 with results. 43 studies were not matched to the original report.

## Comparison of Registry Searches with Original Review

The original report included 98 studies (61 randomized controlled trials in 82 articles, and 37 longitudinal observational studies in 65 articles). We compared our registry search yield with our original report to identify studies (1) registry record present, included in original review; (2) registry record present, not included in original review; and (3) no registry record, included in original review. See Figure 1.

### Studies Identified via Registry Searches and Found in Original Review

Overall, 69 studies in 76 records identified through registry searches met full criteria for inclusion in the original report. Of these, 26 studies (in 27 registry records) were included in the original report (25 RCTs, 1 observational Study); 22 of these were found in ClinicalTrials.gov, 3 were found in ICTRP, and 1 was identified in both registries (see Table 1 for the overall description of studies; the subsequent tables highlight differences between registry records and articles). Of the 26 studies in both sources, only 4 studies (in 4 records) included eligible results in the registry records. In general, the agreement between the registry record and the published paper was good when the information was given in both. A fifth record of a factorial study reported results, but no comparison between the n-3 FA and no n-3 FAs was reported in the record. Full information on the comparison of results for the four studies that have them is in the Results section and Table 3 below.

Table 1 Overall description of studies in both the report and registry from the registry records

Study Identifier Country/ies Study Name | Registry | Population | Dates | N total | Study design: Intervention | Intermediate Outcomes | Clinical Outcomes
Registry record reported results
NCT01242527 US, Denmark, Netherlands, Hungary, India, Russia, Ukraine EVOLVE | CT.gov | At risk | 2011–2012 | 399 | RCT: Fish oil (EPA+DHA) 2, 3, or 4 g/d vs. Placebo | Lipids
NCT01408303 US ESPRIT | CT.gov | At risk | 2011–2012 | 646 | RCT: Fish oil (EPA+DHA) 2 or 4 g/d vs. Placebo | Lipids
NCT01198275 Italy ATRIA | CT.gov | CVD, existing | 2006–2008 | 199 | RCT: Fish oil (EPA+DHA) 0.850–0.882 g/d vs. Placebo | | Arrhythmia event
NCT00781950 Canada FLAXPAD | CT.gov | CVD, existing | 2008–2014 | 110 | RCT: ALA 30 g/d vs. Placebo | BP, Lipids | Cardiac event, Stroke/TIA, Death
Registry record did not report results
NCT00005133 US CHS | CT.gov | Healthy | 1988–2009 | nd | Observational - Quantile: unclear n-3 | | Cardiac event, Stroke/TIA
NCT01313988 Sweden | CT.gov | Healthy | 2011–2012 | 332 | RCT: All n-3 PUFA vs. Placebo | Lipids
NCT00110838 Germany, Netherlands, UK, Austria, Belgium, Czech Republic, Poland, Switzerland SOFA | CT.gov | Healthy | 2010–2011 | 256 | RCT: Fish oil (EPA+DHA) 2 g/d vs. Placebo | Lipids
NCT00266292 Denmark | CT.gov | Healthy | 2005–2006 | 60 | RCT: Fish oil (EPA+DHA) vs. Placebo | BP, Lipids
NCT01856179 Germany | CT.gov | Healthy | 2011–2012 | 78 | RCT: SDA 15–18 g/d vs. nd | Lipids
NCT00317707 Italy | CT.gov | At risk | 2004–2011 | 12513 | RCT: All n-3 PUFA vs. Placebo | | Cardiac event, Death
NCT00141232/ISRCTN76737502 UK AFFORD | ICTRP/ | At risk | 2004–2006 | 810 | RCT: Fish oil (EPA+DHA) vs. Placebo | Lipids
NCT00246701 US COMBOS | CT.gov | At risk | 2005–2006 | 256 | RCT: Fish oil (EPA+DHA) vs. Placebo | Lipids
NCT00069784 Canada ORIGIN | CT.gov | At risk | 2003–2011 | 12537 | RCT: Fish oil (EPA+DHA) 0.84 g/d vs. Placebo | | Cardiac event, Stroke/TIA, Death
NCT01758601 Spain WISH-CARE | CT.gov | At risk | 2010–2012 | 273 | RCT - XO: Fish oil (EPA+DHA) 1 serving of hake/day vs. no intervention | Lipids
NCT00231738 Japan JELIS | CT.gov | At risk | 1996–2004 | 18000 | RCT: EPA 1.8 g/d vs. nd | | Cardiac event, Stroke/TIA, Death
NCT01047501 US ANCHOR | CT.gov | At risk | 2009–2011 | 702 | RCT: EPA 2 or 4 g/d vs. Placebo | Lipids
NCT01351012 Canada COMIT | CT.gov | At risk | 2010–2012 | 140 | RCT - XO: ALA, DHA + ALA DHA 7.2, ALA 4.2–13.8 vs. ALA 4.2–13.8 g/d | Lipids
DRKS00006232 Germany MSX | CT.gov | At risk | 2009–2009 | 81 | RCT: ALA 3.5 g/d vs. ALA 0.9 g/d | BP, Lipids
NCT00004558 US | ICTRP | CVD, existing | 1999–2004 | 200 | RCT: Omega-3 (Unspecified) vs. Placebo | | Arrhythmia event
NCT00127452 Netherlands Alpha Omega | CT.gov | CVD, existing | 2002–2010 | 4837 | RCT: All n-3 PUFA Fish oil 0.4 g/d, ALA 2 g/d vs. Placebo | | Cardiac event, Stroke/TIA, Arrhythmia event, PVD event, Death
NCT00251134 Germany OMEGA | CT.gov | CVD, existing | 2003–2008 | 3800 | RCT: All n-3 PUFA 1 g/d vs. Placebo | | Cardiac event, Arrhythmia event, Death
NCT00336336 Italy GISSI-HF | CT.gov | CVD, existing | 2002–2008 | 6975 | RCT: All n-3 PUFA 1 g/d vs. Placebo | | Cardiac event, Stroke/TIA, Arrhythmia event, Death
ISRCTN41926726 France SU.FOL.OM3 | CT.gov | CVD, existing | 2003–2009 | 2400 | RCT: Fish oil (EPA+DHA) 0.6 g/d vs. Placebo | | Cardiac event, Stroke/TIA, Death
ISRCTN66664610 UK MARINA | ICTRP | CVD, existing | 2008–2010 | 360 | RCT: Fish oil (EPA+DHA) 0.45, 0.9, or 1.8 g/d vs. Placebo | BP, Lipids
NCT00004559 US FAAT | ICTRP | CVD, existing | 2000–2005 | nd | RCT: Fish oil (EPA+DHA) 4 g/d vs. Placebo | | Arrhythmia event
NCT00597220 Argentinia FORWARD | CT.gov | CVD, existing | 2008–2011 | 1600 | RCT: Fish oil (EPA+DHA) 1 g/d vs. Placebo | | Stroke/TIA, Arrhythmia event

RCT: randomized controlled trial; XO: crossover tiral; CT.gov: ClinicalTrials.gov; ICTRP: International Clinical Trials Registry Platform; CVD: cardiovascular disease; NRCS: non-randomized comparative study; TIA: transient ischemic attack; PVD: peripheral vascular disease; BP: blood pressure; EPA: eicosapentaenoic acid; DHA: docosahexaenoic acid; ALA: alphalinolenic acid; PUFA: polyunsaturated fatty acids; SDA: stearidonic acid

Table 3 Results

Study Year PMID Region^**^ | Outcome | Int (n-3 FA) | Control | F/up Time | Int n/N, % or N per arm for continuous outcomes | Ctrl n/N,% or N per arm for continuous outcomes | Effect Size | Reported P value
Marine oil vs. Placebo
Nodari 2011 21844082 Italy | arrhythmia_AFib (recurrence of AFib) | EPA+DHA (0.850–0.882 g/d (marine oil)) | Placebo | 1 y | 15 / 100, 15% | 25 / 99, 25% | OR 0.52 (0.26, 1.06)^a^ | NR
NCT01198275 (Nodari 2011 21844082) | arrhythmia_AFib (no Atrial Fibrillation recurrence at 1-year followup)^*^ | EPA+DHA (0.850–0.882 2 g/d (Omacor)) | Placebo | 1 y | 61/100, 61% | 34/99 34% | OR 0.441 (0.292, 0.666) These results are not in the paper | p<0.05
Maki 2013 23998969 US | lipid_LDL cholesterol | EPA+DHA (4 g/d total oil -free fatty acid oil) | Placebo | 1.5 mo | 207 | 211 | −0.5 (−4.1, 3.1) (−6%) | p<0.0001
NCT01408303 (Maki 2013 23998969 US) | lipid_LDL cholesterol | EPA+DHA (4 g/d Epanova) | Placebo | 1.5 mo | 204 | 210 | −6% | p<0.0001
Maki 2013 23998969 US | lipid_LDL cholesterol | EPA+DHA (4 g/d total oil -free fatty acid oil) | 2 g/d total oil (free fatty acid oil) [nd] | 1.5 mo | 207 | 209 | −3.7 (−7.3, −0.1) (3%)
NCT01408303 (Maki 2013 23998969 US) | lipid_LDL cholesterol | EPA+DHA (4 g/d Epanova) | EPA/DHA((2 g/d total oil (Epanova) | 1.5 mo | 204 | 209 | −3.05%
Maki 2013 23998969 US | lipid_LDL cholesterol | EPA+DHA 2 g/d free fatty acid oil) | Placebo | 1.5 mo | 209 | 211 | −3% | p<0.05
NCT01408303 (Maki 2013 23998969 US) | lipid_LDL | EPA+DHA (4 g/d Epanova) | Placebo | 1.5 mo | 209 | 210 | −2.95% | p<0.05
Kastelein 2014 24528690 Europe | lipid_Tg | EPA+DHA (EPA: 2.20 g/d, DHA: 0.80 g/d) | Placebo | 12 wk | 99 | 98 | −173.1 (−250.3, −95.8) | p<0.001
NCT01242527 (Kastelein 2014 24528690) | lipid_Tg | EPA+DHA (Epanova 4g/d) | Placebo | 12 wk | 95 | 98 | −26.6% (Matches % change in paper) | p<0.001
Kastelein 2014 24528690 Europe | lipid_Tg | EPA+DHA (EPA: 1.65 g/d, DHA: 0.60 g/d) | Placebo | 12 wk | 97 | 98 | −156.3 (−238.8, −73.8) | p<0.01
NCT01242527 (Kastelein 2014 24528690) | lipid_Tg | EPA+DHA (Epanova 3g) | Placebo | 12 wk | 94 | 98 | −21.2% (Matches % change in paper) | p<0.01
Kastelein 2014 24528690 Europe | lipid_Tg | EPA+DHA (EPA: 1.10 g/d, DHA: 0.40 g/d) | Placebo | 12 wk | 99 | 98 | −156.4 (−238.1, −74.6) | p<0.01
NCT01242527 (Kastelein 2014 24528690) | lipid_Tg | EPA+DHA (Epanova 2g) | Placebo | 12 wk | 95 | 98 | −21.68% (Matches % change in paper) | p<0.01
NCT00781950 (Rodriguez-Leyva 2013 24126178) | MACE (All-cause Mortality, Cardiovascular Mortality, Stroke, and Myocardial Infarctions) | ALA (flaxseed) | Placebo (wheat and wheat bran) | 1 y | 5/58 (8.6%) | 4/52 (7.7%) | OR 1.13 (0.29, 4.46) This outcome is not in the paper | NS
NCT00781950 (Rodriguez-Leyva 2013 24126178) | death_all cause | ALA (flaxseed) | Placebo (wheat and wheat bran) | 1 y | 1/58 1.7% | 0/52, 0% | OR 2.73 (0.11, 68.64) This outcome is not in the paper | NS
Rodriguez-Leyva 2013 24126178 | cardiac_MI | ALA (5.9 g/d flaxseed) | Placebo | 1y | 2/58 3.4% | 4/52 7.7% | OR 0.43 (0.08, 2.44) Slight difference | NS
NCT00781950 (Rodriguez-Leyva 2013 24126178) | cardiac_MI | ALA (flaxseed) | Placebo (wheat and wheat bran) | 1 y | 1/58 1.7% | 3/52 5.8% | OR 0.29 (0.03, 2.84) Slight difference | NS
Rodriguez-Leyva 2013 24126178 | cerebro_Stroke | ALA (5.9 g/d flaxseed) | Placebo | 1y | 1/58 1.7% | 2/52 3.8% | OR 0.44 (0.04, 4.98) Different in direction and magnitude | NS
NCT00781950 (Rodriguez-Leyva 2013 24126178) | cerebro_Stroke | ALA (flaxseed) | Placebo (wheat and wheat bran) | 1 y | 3/58 5.2% | 1/52 1.9% | OR 2.78 (0.28, 27.61) Different in direction and magnitude | NS
Rodriguez-Leyva 2013 24126178 | bp_DBP | ALA (5.9 g/d flaxseed) | Placebo | 1y | 45 | 41 | −2.1 (−7.2, 3.0)
NCT00781950 (Rodriguez-Leyva 2013 24126178) | bp_DBP | ALA (flaxseed) | Placebo (wheat and wheat bran) | 1 y | 45 | 41 | 71.8 (1.7) vs. 78.5 (1.5) Final values; no baselines given. Matches paper.
Rodriguez-Leyva 2013 24126178 | bp_SBP | ALA (5.9 g/d flaxseed) | Placebo | 1y | 45 | 41 | −7.3 (−15.4, 0.80)
NCT00781950 (Rodriguez-Leyva 2013 24126178) | bp_SBP | ALA (flaxseed) | Placebo (wheat and wheat bran) | 1 y | 45 | 41 | 136.2 (3.8) vs.145.6 (3.4) Final values; no baselines given. Matches paper.

* discrepancies are indicated by bold italic text;

** for each shading the first row (with no NCT number) is the published study from the original report, the second row is the corresponding registry record; AFib = atrial fibrillation, LDL = low-density lipoprotein, HDL = high-density lipoprotein, MI = myocardial infarction, DBP = diastolic blood pressure, SBP = systolic blood pressure.

#### Study Design

For all 26 studies found in both the report and registries, we were able to extract some study design information via registry records. When possible, study design information extracted from the registry record was compared to corresponding publications to assess if changes in analysis plan occurred. In general, agreement was very good between the registry record and the report, particularly in terms of population and eligibility criteria. There were some small disagreements in study start date, duration of intervention, and reporting of industry relationship when the only role of the sponsor was solely to provide materials. See Appendix E, Tables 1 and 2 for full details.

#### Outcomes

Outcomes of interest described in the original review (see Appendix B), were identified in registry records and in publications and compared. Registry records include data entry fields for primary and secondary outcomes and these measures were extracted and characterized as such. Disposition of primary outcomes found in publications were determined if they were 1) explicitly stated as such, 2) the outcome used in reported power calculations, or 3) where implied by focus of the original article.

We identified several discrepancies between outcomes reported in registry records and resulting publications (Table 2). The overwhelming number discrepancies (24 outcomes in 12 papers) had to do with more outcomes being reported in the paper than were prespecified in the record. In general, these were intermediate outcomes (e.g., lipids and blood pressure), though in three papers they were clinical outcomes, including nonfatal stroke, myocardial infarction, and revascularization, among others). All of the added clinical and blood pressure outcomes were reported as not having a significant difference between groups. As would be expected, triglycerides were consistently reported as significantly favoring the Omega-3 group, but cholesterol overall showed a nonsignificant difference.

Table 2 Outcome discrepancies

Study name, Date, PMID, Registry number | N record/N publication | Current prespecified outcome (from registry) | In papers (as primary/secondary) (time point) | In Registry Record (as primary/secondary) (time point) | Outcome (favors n-3, favors other, not significant (NS), results not reported (ND))
Baxheinrich, 2012, 22894911, DRKS00006232 | 81/81 | Blood pressure | Secondary (3 and 6 months) | Secondary (3 and 6 months) | Favors n-3
Baxheinrich, 2012, 22894911, DRKS00006232 | 81/81 | Lipids | Secondary (3 and 6 months) | Secondary (3 and 6 months) | Favors n-3 for TG; NS for others
Bosch, 2012, 22686415, NCT00069784 | 12537/12536 | MACE: Composite of the First Occurrence of Cardiovascular (CV) Death, Nonfatal Myocardial Infarction, Nonfatal Stroke, Revascularization Procedure or Hospitalization for Heart Failure | Secondary (6+ years), except for “death from cardiovascular causes’” which is also primary in the paper | Primary (mean 6.2 years) | NS
Bosch, 2012, 22686415, NCT00069784 | 12537/12536 | Death from cardiovascular causes | Primary (6+ years) | Primary (mean 6.2 years) | NS
Bosch, 2012, 22686415, NCT00069784 | 12537/12536 | Total mortality (all causes) | Secondary (6+ years) | Secondary (mean 6.2 years) | NS
Bosch, 2012, 22686415, NCT00069784 | 12537/12536 | Lipids | Secondary (6+ years) | | NS
Bosch, 2012, 22686415, NCT00069784 | 12537/12536 | Blood pressure | Secondary (6+ years) | | NS
Brinton, 2013, 23835245, NCT01047501 | 702/687 | Lipids (Tg) | Primary (3 months) | Primary (12 weeks) | Favors n-3
Brinton, 2013, 23835245, NCT01047501 | 702/687 | Lipids (other) | Secondary (3 months) | Secondary (12 weeks) | Favors n-3
Brouwer, 2006, 16772624, NCT00110838 | 546/546 | ICD intervention/device insertion | Primary (1 year) | Primary (1 year) | NS
Brouwer, 2006, 16772624, NCT00110838 | 546/546 | Total mortality (all causes) | Secondary (1 year) | Secondary (1 year) | NS
Brouwer, 2006, 16772624, NCT00110838 | 546/546 | Myocardial infarction | Secondary (1 year) | Secondary (1 year) | NS
Brouwer, 2006, 16772624, NCT00110838 | 546/546 | Cardiac mortality | Secondary (1 year) | Secondary (1 year) | NS
Brouwer, 2006, 16772624, NCT00110838 | 546/546 | Arrythmic events (VF/VT) | Secondary (1 year) | Secondary (1 year) | NS
Damsgaard, 2008, 18492834, NCT00266292 | 60/64 | Lipids | Primary (8 weeks) | Primary (2 months) | NS
Damsgaard, 2008, 18492834, NCT00266292 | 60/64 | Blood pressure | | Primary (2 months) | ND
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | MACE: Combination of myocardial infarction, cerebral vascular ischemic accident or cardiovascular deaths | Primary (median 4.7 years) | Primary (nd) | NS
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | Total mortality (all causes) | Secondary (median 4.7 years) | Secondary (nd) | Favors other
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | CVD mortality | Secondary (median 4.7 years) | Secondary (nd) | NS
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | Myocardial infarction | Secondary (median 4.7 years) | Secondary (nd) | NS
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | Acute Coronary Syndrome | Secondary (median 4.7 years); as part of a composite outcome | Secondary (nd) | NS
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | Ischemic cerebral vascular accidents (stroke) | Secondary (median 4.7 years) | Secondary (nd) | NS
Galan, 2010, 21115589, ISRCTN41926726 | 2400/2501 | Revascularization | Secondary (median 4.7 years) | Secondary (nd) | NS
Holman, 2009, 19002433, NCT00141232 and ISRCTN76737502 | 810/658 | Lipids (Tg) | Primary (4 months) | Primary (4 months) | Favors n-3
Holman, 2009, 19002433, NCT00141232 and ISRCTN76737502 | 810/658 | Blood pressure | Secondary (4 months) | | NS
Jones, 2014, 24829493, NCT01351012 | 140/130 | Lipids | Secondary (4 weeks) | Secondary (4 weeks) | Favors n-3
Jones, 2014, 24829493, NCT01351012 | 140/130 | Blood pressure | Secondary (4 weeks) | Secondary (4 weeks) | Favors n-3
Kastelein, 2014, 24528690, NCT01242527 | 399/393 | Lipids (Tg) | Primary (12 weeks) | Primary (12 weeks) | Favors n-3
Kastelein, 2014, 24528690, NCT01242527 | 399/393 | Lipids (other) | Secondary (12 weeks) | | Favors n-3
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | Major cardiovascular events, which comprises fatal cardiovascular diseases (CVD), non-fatal myocardial infarction, non-fatal cardiac arrest, non-fatal stroke and cardiac interventions (PCI and CABG) | Primary (40 months) | Primary (40 months) | NS
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | cardiovascular diseases (CVD | Secondary (40 months) | Secondary (40 months) | NS
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | Cardiac mortality | Secondary (40 months) | Secondary (40 months) | NS
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | Arrythmia | Secondary (40 months) | | NS
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | Total mortality (all causes) | Secondary (40 months) | Secondary (40 months) | NS
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | Lipids (in appendix) | Secondary (40 months) | | NS
Kromhout, 2010, 20929341, NCT00127452 | 4837/4837 | Blood pressure (in appendix) | Secondary (40 months) | | NS
Kuhnt 2014, 24553695, NCT01856179 | 78/59 | EPA concentrations | Primary (56 days) | Primary (2 months) | N/A (not an outcome of interest for the report)
Kuhnt 2014, 24553695, NCT01856179 | 78/59 | Lipids | Secondary (2 months) | | Favors n-3
Kuhnt 2014, 24553695, NCT01856179 | 78/59 | Blood pressure | Secondary (2 months) | | Favors n-3
Leaf, 2005, 16267249, NCT00004559 | Nd/402 | VT or VF event | Primary (12 months) | Primary (nd) | NS
Leaf, 2005, 16267249, NCT00004559 | Nd/402 | Total mortality (all causes) | Secondary (1 year) | | NS
Leaf, 2005, 16267249, NCT00004559 | Nd/402 | Cardiac mortality | Secondary (1 year) | | NS
Leaf, 2005, 16267249, NCT00004559 | Nd/402 | Sudden cardiac death | Secondary (1 year) | | NS
Macchia, 2013, 23265344, NCT00597220 | 1600/586 | Atrial fibrillation | Primary (12 months) | Primary (12 months) | NS
Macchia, 2013, 23265344, NCT00597220 | 1600/586 | Total mortality (all causes) | Secondary (12 months) | Secondary (12 months) | NS
Macchia, 2013, 23265344, NCT00597220 | 1600/586 | MACE: all-cause mortality, nonfatal stroke, nonfatal acute myocardial infarction (AMI), systemic embolism, heart failure development, or severe bleeding | Secondary (12 months) | | NS
Macchia, 2013, 23265344, NCT00597220 | 1600/586 | hospitalizations for CV reasons | Secondary (12 months) | Secondary (12 months) | NS
Macchia, 2013, 23265344, NCT00597220 | 1600/586 | Thromboembolism | Secondary (12 months) | Secondary (12 months) | NS
Maki, 2010, 20451686, NCT00246701 | 256/254 | Lipids | Primary (8 weeks) | Primary (8 weeks) | Favors n-3
Maki, 2013, 23998969, NCT01408303 | 646/627 | Lipids | Primary (1.5 months) | Primary (6 weeks) | Favors n-3
Nodari, 2011, 21844082, NCT01198275 | 199/133 | Atrial fibrillation (maintenance of sinus rhythm) | Primary (1 year) | Primary (1 year) | Favors n-3
Nodari, 2011, 21844082, NCT01198275 | 199/133 | Time to a First Recurrence of Atrial fibrillation | Secondary (median 718 days) | Secondary (12 months) | Favors n-3
Raitt, 2005, 15956633, NCT00004558 | 200/200 | VT or VF | Primary (median of 718 days) | Primary (nd) | NS
Raitt, 2005, 15956633, NCT00004558 | 200/200 | Total mortality (all causes) | Secondary (2 years) | Secondary (nd) | NS
Raitt, 2005, 15956633, NCT00004558 | 200/200 | Hospitalization rates | Secondary (2 years) | Secondary (nd) | NS
Raitt, 2005, 15956633, NCT00004558 | 200/200 | Cardiac mortality | Secondary (2 years) | | NS
Raitt, 2005, 15956633, NCT00004558 | 200/200 | Sudden Cardiac Death | Secondary (2 years) | | NS
Raitt, 2005, 15956633, NCT00004558 | 200/200 | Revascularization | Secondary (2 years) | | NS
Raitt, 2005, 15956633, NCT00004558 | 200/200 | Myocardial infarction | Secondary (2 years) | | NS
Ras, 2014, 25122648, NCT01313988 | 332/314 | Lipids (Tg) | Primary (1 month) | Primary (4 weeks) | Favors n-3
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | Sudden cardiac death | Primary (1 year) | Primary (12 months) | NS
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | Total mortality (all causes) | Secondary (1 year) | Secondary (12 months) | NS
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | MACCE: Total mortality, re-infarction or stroke | Secondary (1 year) | Secondary (12 months) | NS
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | Total rehospitalisation | Secondary (1 year) | Secondary (12 months) | NS
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | VT or VF | Secondary (1 year) | Secondary (12 months) | NS
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | Arrhythmia device insertion | Secondary (1 year) | Secondary (12 months) | Favors other
Rauch, 2010, 21060071, NCT00251134 | 3800/3804 | Revascularization | Secondary (1 year) | Secondary (12 months) | NS
Rodriguez-Leyva, 2013, 24126178, NCT00781950 (outcome information from published protocol, PMID 21616170) | 110/87 | Total mortality (all causes) | Secondary (1 year) | Primary (1 year) | NS
Rodriguez-Leyva, 2013, 24126178, NCT00781950 (outcome information from published protocol, PMID 21616170) | 110/87 | CVD mortality | Secondary (1 year) | Primary (1 year) | NS
Rodriguez-Leyva, 2013, 24126178, NCT00781950 (outcome information from published protocol, PMID 21616170) | 110/87 | Stroke | Primary (1 year) | Primary (1 year) | NS
Rodriguez-Leyva, 2013, 24126178, NCT00781950 (outcome information from published protocol, PMID 21616170) | 110/87 | Myocardial infarction | Primary (1 year) | Primary (1 year) | NS
Rodriguez-Leyva, 2013, 24126178, NCT00781950 (outcome information from published protocol, PMID 21616170) | 110/87 | Blood pressure | Secondary (1, 6, and 12 months) | Secondary (1 year) | Favors n-3
Rodriguez-Leyva, 2013, 24126178, NCT00781950 (outcome information from published protocol, PMID 21616170) | 110/87 | Lipids | Secondary (1, 6, and 12 months) | Secondary (1 year) | ND
Roncaglioni, 2013, 23656645, NCT00317707 | 12513/12513 | MACE: death from cardiovascular causes or hospital admission from cardiovascular causes | Primary (5 years) | Primary (5 years) | NS
Roncaglioni, 2013, 23656645, NCT00317707 | 12513/12513 | Lipids (in appendix) | Secondary (5 years) | | Favors n-3
Roncaglioni, 2013, 23656645, NCT00317707 | 12513/12513 | Blood pressure (in appendix) | Secondary (5 years) | | NS
Sanders, 2011, 21865334, ISRCTN66664610 | 360/310 | Lipids | Secondary (1 year) | Secondary (6 months, 12 months) | Favors n-3
Sanders, 2011, 21865334, ISRCTN66664610 | 360/310 | Blood pressure | Secondary (1 year) | | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Total mortality (all causes) | Primary (stated) (3.9 years) | Primary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Total mortality (all causes) or hospitalization for any reason | | Primary (from enrollment to 1252 deaths in R2 arm) | Favors n-3 (when adjusted)
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | CVD mortality | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | Favors n-3 (when adjusted)
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Hospitalization for any reason | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | Favors n-3 (when adjusted)
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Heart failure | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Sudden cardiac death | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Congestive heart failure | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Myocardial infarction | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Stroke death | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Stroke | Secondary (3.9 years) | Secondary (from enrollment to 1252 deaths in R2 arm) | NS
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Lipids | Secondary (3.9 years) | | Favors n-3
Tavazzi, 2008, 18757090, NCT00336336 | 6975/6975 | Blood pressure | Secondary (3.9 years) | | NS
Vazquez, 2014, 24462043, NCT01758601 | 273/273 | Lipids | Primary (2 months) | Primary (8 weeks) | Favors n-3
Vazquez, 2014, 24462043, NCT01758601 | 273/273 | Blood pressure | Secondary (2 months) | Secondary (8 weeks) | Favors n-3
Yokoyama, 2007, 17398308, NCT00231738 | 18000/9319 | Major coronary events (sudden cardiac death, fatal and nonfatal myocardial infarction, unstable angina pectoris including hospitalization for ischemic episodes, events of angioplasty/stenting or coronary artery bypass grafting) | Primary (4.6 years) | Primary (nd) | Favors n-3
Yokoyama, 2007, 17398308, NCT00231738 | 18000/9319 | Total mortality (all causes) | Secondary (4.6 years) | Secondary (nd) | NS
Yokoyama, 2007, 17398308, NCT00231738 | 18000/9319 | Stroke | Secondary (4.6 years) | Secondary (nd) | NS
Yokoyama, 2007, 17398308, NCT00231738 | 18000/9319 | Peripheral artery disease | Secondary (4.6 years) | Secondary (nd) | ND
Yokoyama, 2007, 17398308, NCT00231738 | 18000/9319 | Lipids | Secondary (4.6 years) | | Favors n-3
Yokoyama, 2007, 17398308, NCT00231738 | 18000/9319 | Blood pressure | Secondary (4.6 years) | | NS

In three cases, a record prespecified a clinical outcome as primary, and it was either reported as secondary or not at all in the paper. In the study by Bosch, the prespecified outcome was a composite of “the First Occurrence of Cardiovascular (CV) Death, Nonfatal Myocardial Infarction, Nonfatal Stroke, Revascularization Procedure or Hospitalization for Heart Failure.” All of these outcomes were reported in the paper as secondary outcomes, except Cardiovascular (CV) Death, which was reported as primary. None of these results was significantly different between groups.^24^ The paper by Damsgaard reported the prespecified lipid outcomes, which were not significant, but not the prespecified blood pressure outcomes.^25^ For the study by Rodriguez-Leyva, we went to their published protocol,^26^ which differed from the record in two outcomes (total and CVD mortality), which were reported as not significantly different between groups in the paper. Both of these outcomes were specified as primary in the record and secondary in the published protocol. It is worth noting that the paper also reported nonsignificant differences for the other two primary outcomes (stroke and MI). In general, this suggests that there is probably not major problem with selective outcome reporting in this body of literature.^27^

#### Baselines

For the four studies that had results data in both the registry record and publications,^27–30^ baseline data, results, and adverse events were compared. The baseline data provided in registry records were limited to age, gender, and in one record^29^ race. All of the baselines provided matched the corresponding publications exactly (for further details, see Appendix E, Table E-5).

#### Results

The results, as reported in both the records and the publications, are given in Table 3. In one paper there was a discrepancy in how the results were reported, which lead to a difference in significance.^30^ However, the significant results were reported in the registry record, while the non-significant findings were reported in the paper, so there is little indication of reporting bias. In addition, the odds ratio reported in the record falls within the confidence intervals of that in the report, and so is unlikely to differ in either direction or magnitude.

In a second study, the record and the paper do not agree in terms of outcomes reported or results given.^27^ This is a recent study so it is possible that the paper for the clinical outcomes is still in process. One outcome, all-cause mortality, was given in the record but not in either paper. This outcome was not found to be significant. A second outcome, stroke, was reported in both the paper and the record, but the results differed in both direction and magnitude. A third outcome, myocardial infarction, was reported slightly differently, but neither odds ratio was found to be statistically significant.

Otherwise, the discrepancies were small, mostly involved the number analyzed, and did not affect the results. Full details are given in Table 3; discrepancies are indicated by bold/italic text.

#### Adverse Events

Both the papers and the records with results mentioned adverse events. The reported adverse events matched the paper in all but one study. Nausea, which is thought to be an adverse effect of Omega-3 supplementation, was reported in the record for the Rodriguez-Leyva study but was not reported in the paper.^27^ Full details are given in Appendix E, Table E-6.

#### Risk of Bias

We evaluated the risk of bias for all studies identified in both the report and the records. In general, there was insufficient evidence to make judgements on specific risk of bias items. Where the evidence was sufficient, the records and reports agreed most of the time. Details are in Appendix E, Tables E-7 and E88. We did not find any new information that would change our initial risk of bias or strength or evidence assessments.

### Relevant Studies Identified via Registry Searches and Not Found in Original Review

Of the 69 studies in 76 records identified through registry searches that met full criteria for inclusion in the original report, 43 studies (in 49 records) were not found in the original review (42 randomized controlled trials and 1 Observational Study); 28 (57%) records in ClinicalTrials.gov and 21 records in ICTRP (43%). The completion status of studies described in the 49 records are as follows; completed n = 23, ongoing n= 10 and unknown status n=13. The study enrollment estimates for studies completed as of December 31, 2016 account for a projected 20088 participants. An additional 145275 participants were estimated to enroll in the remaining studies (ongoing and unknown status). The mean start date of the studies included in the report was about 5 years earlier than the mean start date of the studies not in the report (Figure 2). In addition, many of the studies not in the report were not completed at the time of the search, which explains why they did not have publications or results.

Figure 2 Timing of studies

Red lines indicate studies in the review; black lines indicate studies not in the review. The red dashed line is the mean start date for studies in the review. The black dashed line is the mean start date for studies not in the review. The blue solid line is the date of the search. Lines with arrows indicate records that did not give an estimated completion date. In two cases, no start date was given, so we used the date of entry into the registry.

Figure 2 shows the start and end dates of all studies for which records were found. In general, it shows that the studies that were in the review were on average 5 years older than the studies that were not found in the review. Many of the studies not found in the review were still ongoing at the time of the registry search.

Reviewing the evidence map for the original report, we identified publications for seven of these studies, which did not meet inclusion/exclusion criteria for the original report. Details about these studies are in Table 4. A single record yielded a new publication emanating from a study included in our original report. This new manuscript was published in the intervening time since the last update of the report search. Relevant results from this study were already identified in another publication and included in the report, the results in this newly identified manuscript were added to the report, but did not change the direction or magnitude of the results for those outcomes.

Table 4 Overall description of studies in the registry but not the report

Study Identifier Country/ies Study Name | Registry | Population | Date (start/end) | N total* | Study design: Intervention | Intermediate Outcomes | Clinical Outcomes
CTRI/2012/08/002856, India | ICTRP (Clinical Trial Registry of India) | Healthy/obese | 2012-? | 60 | RCT: EPA 180 mg + DHA 120 mg capsules vs. EPA 180 mg + DHA 120 mg capsules capsules + probiotic capsules vs. probiotic capsules vs. placebo | BP/Lipids | Cardiac event/arrhythmia
NCT00232219, Australia | CT.gov | CVD, existing | 2003–2013 | 200 | RCT: Fish oil capsules (1.8g/d of EPA+DHA) | | Arrhythmia event
NCT02183285, no location listed | CT.gov | Healthy | 2003–2004 | 203 | RCT: Multivitamin, Multimineral + Omega-3 Fatty Acids vs Multivitamin, Multimineral without Omega-3 Fatty Acids vs placebo | BP/Lipids | AEs
NCT01350973, no location listed | CT.gov | Dyslipidemia | 2009–2010 | 611 | RCT: Omacor 2 g, capsules, orally, once daily for up to 12 weeks vs. Omacor 2 g, capsules, orally, twice daily for up to 12 weeks vs. EPA-E, 0.6 g, orally, three-times daily for up to 12 weeks. | BP/Lipids | AEs
NCT01350999, no location listed | CT.gov | Dyslipidemia | 2009–2011 | 503 | RCT: Omacor 2 g, capsules, orally, once daily for up to 52 weeks vs. Omacor 2 g, capsules, orally, twice daily for up to 52 weeks vs. EPA-E, 0.6 g, orally, three-times daily for up to 52 weeks. | BP/Lipids, HTN
NCT01048502, US | CT.gov | CVD, existing | 2010–2011 | 100 | RCT: Tricor 145 mg/day vs. Lovaza 900 mg/day vs. Lovaza 3600 mg/day vs placebo | BP/Lipids
NCT02239198, US | CT.gov | Healthy | 2007–2008 | 150 | RCT: Complete nutrition bar with omega-3 fatty acids vs. Nutrition bar without omega-3 fatty acids vs. Nutrition bar without added minerals and vitamins | BP/Lipids
NCT00135226, UK | CT.gov | DM | 2005–2016 | 15480 | RCT: Aspirin 100 mg/day + Omega-3-Ethyl Esters 1g/day vs. Aspirin 100 mg/day + Placebo vs. Placebo + Omega-3-Ethyl Esters 1g/day vs. Placebo | | Cardiac events, stroke/TIA
NCT01810003, Canada | CT.gov | CVD, existing | 2013–2016 | 170 | RCT: DHA 3g/day (10 wks) vs. EPA 3g/day (10 wks) vs. placebo | BP/Lipids
NCT02210767, US | CT.gov | Healthy | 2014–2016 | 50 | RCT: 2 oz walnuts/day (ALA) vs. fatty acids not from walnuts vs. low ALA diet | BP/Lipids
NCT02285166, Japan | CT.gov | Dyslipidemia | 2014–2019 | 14000 | RCT: Lotriga 2–4g/day vs. standard antihyperlipidemic therapy | BP/Lipids, HTN | Cardiac events, stroke/TIA, arrhythmia, PDV, death
NCT01841944, Norway | CT.gov | CVD, existing | 2012–2019 | 1400 | RCT: Pikasol (1.8 g EPA+DHA)/day vs. placebo | | Cardiac events, stroke/TIA, arrhythmia, death
NCT01320228, Denmark | CT.gov | Healthy | 2011–2012 | 69 | RCT: Alli (60 mg t.i.d) + 5 g flaxseed fibers and 1200 mg Ca from Capolac vs. Alli (60 mg t.i.d) + 5 g flaxseed fibers vs. Alli (60 mg t.i.d) + 1200 mg Ca from Capolac vs. Alli (60 mg t.i.d) + placebo | BP/Lipids
NCT02294526, no location listed | CT.gov | DM | 2012–2013 | 35 | RCT: Sardine (100g per day, 5 days a week) diet vs no sardine diet | BP/Lipids
NCT01492361, US, Australia, Canada, India, Netherlands, New Zealand, Poland, Romania, Russian Federation, South Africa, Ukraine | CT.gov | CVD, existing | 2011–2017 | 8000 | RCT: VASCEPA (icosapent ethyl) vs. placebo | BP/Lipids | Cardiac events, stroke/TIA, arrhythmia, death
NCT02104817, US, Argentina, Australia, Brazil, Canada, Czech Republic, Denmark, Estonia, Hungary, Italy, Japan, Korea, Latvia, Lithuania, Mexico, Netherlands, New Zealand, Poland, Romania, Russian Federation, South Africa, Taiwan, Ukraine, United Kingdom | CT.gov | Other (mixed) CVD high risk | 2014–2019 | 13000 | RCT: Epanova + statin daily vs. placebo + statin daily | | Cardiac events, stroke/TIA, arrhythmia, death
NCT02243969, Netherlands | CT.gov | Mixed | 2014–2015 | 72 | RCT: Flaxseed oil (ALA) 10g/day (12 wks) vs. placebo | BP/Lipids
NCT01169259, US | CT.gov | Mixed | 2010–2017 | 25874 | RCT: Vitamin D3 2000 IU/day + Omacor, 1 capsule/day vs. Vitamin D3 2000 IU/day + placebo vs. placebo + Omacor, 1 capsule/day vs. placebo | | Cardiac events
NCT02271230, US | CT.gov | CVD, existing | 2014–2020 | 25875 | RCT: Vitamin D 2000 IU/day vs. EPA/DHA 1g/day vs. placebo | | Cardiac events
NCT01785004, US | CT.gov | Healthy | 2012–2015 | 600 | RCT: Vitamin D3 2000 IU/day + Omacor, 1 capsule/day vs. Vitamin D3 2000 IU/day + placebo vs. placebo + Omacor, 1 capsule/day vs. placebo | BP/Lipids
NCT01653678, US | CT.gov | HTN | 2011–2017 | 25875 | RCT: Vitamin D3 2000 IU/day + Omacor, 1 capsule/day vs. Vitamin D3 2000 IU/day + placebo vs. placebo + Omacor, 1 capsule/day vs. placebo | BP/Lipids, HTN
NCT02178410, US | CT.gov | CVD, existing | 2012–2017 | 25875 | RCT: Vitamin D3 2000 IU/day + Omacor, 1 capsule/day vs. Vitamin D3 2000 IU/day + placebo vs. placebo + Omacor, 1 capsule/day vs. placebo | | Cardiac events, arrhythmia, death
NCT02155816, US | CT.gov | Healthy | 2014–2014 | 68 | RCT: Omega 3 (1000mg/day) for 8 wks vs. Omega 7 (210mg/day) and Omega 3 (1000mg/day) for 8 wks vs. placebo | BP/Lipids
NCT00967733, no location listed | CT.gov | CVD, existing | 2009–2009 | 130 | RCT: Flaxseed oil (ALA) 2–4 g/day + olive oil cooking vs. Olive oil pill 1g/day + olive oil cooking vs. Flaxseed oil (ALA) 2–4 g/day + sunflower oil cooking vs. Olive oil pill 1g/day + sunflower oil cooking | BP/Lipids
NCT00422266, India | CT.gov | Dyslipidemia | 2006–2007 | 178 | RCT: Not explicitly described | BP/Lipids
NCT01224249, Denmark | CT.gov | Healthy | 2010–2011 | 102 | Obs: Fish and shellfish 1000 g/week for six months vs. no comparator | BP/Lipids
ACTRN12607000278437, Australia | ICTRP | Healthy | 2007-? | 400 | RCT: DHA 430 mg/EPA 150 mg QID vs. olive oil | BP
DRKS00006742, Germany | ICTRP | HTN | 2015–2015 | 100 | RCT: Milk with DHA 250 mg/day (4 weeks) vs. Milk with beta-glucans 3g/day (4 weeks) vs. Milk with anthocyanins 320mg/day (4 weeks) vs. Milk with DHA 250mg + beta-glucans 3g/day (4 weeks) vs. Milk with DHA 250mg + anthocyanins 320mg/day (4 weeks) | BP/Lipids
JPRN-UMIN000011934, Japan | ICTRP | CVD, existing | 2010–2013 | 80 | RCT: EPA 1800mg + statin therapy/day (2 yrs) vs. Ezetimibe 10 mg + statin therapy/day (2yrs) vs. statin therapy (2yrs) | | Cardiac events, PVD, death
JPRN-UMIN000007956, Japan | ICTRP | CVD, existing | 2012-? | 80 | RCT: EPA 1800 mg/day + statin therapy vs. statin therapy | BP/Lipids
ISRCTN16448451, UK | ICTRP | CVD, existing | 1998–2002 | nd | RCT: fish oil + normal diet vs. normal diet | | Arrhythmia
ISRCTN24439243, Spain | ICTRP | Other (mixed) CVD high risk | 2009–2011 | 250 | RCT: increased fish consumption + normal diet vs. normal diet | BP/Lipids
RBR-5668v4, Brazil | ICTRP | Other (mixed) CVD high risk | 2011–2013 | 87 | RCT: Omega-3 900my/day + dietary guidance vs. dietary guidance | BP/Lipids
IRCT2013080514273N1, no location listed | ICTRP | CVD, existing | 2013–2013 | 60 | RCT: | BP/Lipids
JPRN-UMIN000006416, Japan | ICTRP | CVD, existing | 2009-? | 100 | RCT: Aspirin100 mg/day vs. EPA ethyl ester 1800mg/day + Aspirin100mg/day | BP/Lipids
JPRN-UMIN000007266, Japan | ICTRP | CVD, existing | 2012-? | 200 | RCT: EPA vs. antiplatelet + statins | | Cardiac events, stroke/TIA, PVD, death
JPRN-UMIN000012069, Japan | ICTRP | CVD, existing | 2013–2019 | 3200 | RCT: EPA 1800 mg/day + statin therapy vs. statin therapy | | Cardiac events, stroke/TIA, PVD, death
JPRN-UMIN000016723, Japan | ICTRP | CVD, existing | 2010-? | 200 | RCT: pitavastatin 2 mg/day + EPA 1800 mg/day vs. pitavastatin 2 mg/day | | Cardiac events, stroke/TIA
JPRN-UMIN000018056, Japan | ICTRP | Dyslipidemia | 2015-? | 40 | RCT: DHA+EPA 2g/day (4 wks) at 4 wks, triglycerides >150 mg/dl, dose increased to 4mg/day (8 weeks); triglycerides <150mg/dl, does maintained at 2mg/day vs. observation | BP/Lipids | Cardiac events
JPRN-UMIN000004024, Japan | ICTRP | Dyslipidemia | 2010-? | 100 | RCT: EPA (no other details reported) | BP/Lipids
JPRN-UMIN000012852, Japan | ICTRP | CVD, existing | 2014-? | 100 | RCT: EPA 1800 mg/day + statin therapy vs. statin therapy | | Cardiac events, stroke/TIA, PVD, death
EUCTR2006-006863-22-GB, UK | ICTRP | CVD, existing | 2007-? | 100 | RCT: Cardiozen 500 mg vs. placebo (no other information) | | arrhythmia
EUCTR2005-001354-25-GB, UK | ICTRP | CVD, existing | 2005-? | 150 | RCT: Omacor vs. placebo (no other information) | | Arrhythmia
EUCTR2005-004969-41-IT, Italy | ICTRP | CVD, existing | 2006-? | 266 | RCT: SEACOR 1000MG vs. placebo (no other information) | | Arrhythmia
NCT02103517, China | CT.gov | Healthy | 2014–2015 | 400 | RCT: Omega-3 FA 4gm/day (3 mos) vs. placebo | BP/Lipids
JPRN-UMIN000003947, Japan | ICTRP | CVD, existing | 2010-? | 200 | RCT: EPA 1800 mg/day + statin therapy vs. statin therapy | | Cardiac events, PVD, Death
JPRN-UMIN000012825, Japan | ICTRP | CVD, existing | 2014–2019 | 180 | RCT: Statin vs. Statin + EPA vs. Statin + EPA + DHA | BP/Lipids
NCT01723345, Iran | CT.gov | CVD, existing | 2012–2013 | 90 | RCT: EPA 400 mg + DHA 200 mg 12 h prior to PCI vs standard treatment | | Cardiac events
NCT01422317 Norway OFAMI | CT.gov | CVD, existing | 1995–2002 | 300 | RCT: Fish oil (EPA+DHA) 3.464 g/d vs. Placebo | Lipids | Cardiac event

RCT: randomized controlled trial; XO: crossover tiral; CT.gov: ClinicalTrials.gov; ICTRP: International Clinical Trials Registry Platform; CVD: cardiovascular disease; NRCS: non-randomized comparative study; TIA: transient ischemic attack; PVD: peripheral vascular disease; BP: blood pressure; EPA: eicosapentaenoic acid; DHA: docosahexaenoic acid; ALA: alphalinolenic acid; PUFA: polyunsaturated fatty acids; SDA: stearidonic acid

### Studies Included in the Original Review, with No Registry Record

The original report’s 98 studies included 61 randomized controlled trials in 82 articles and 37 longitudinal observational studies in 65 articles. Of these, we were unable to find a registry record for 72 studies (73%), including 36 randomized controlled trials (59%) and 36 longitudinal observational studies (97%). This may be due to the fact that many of the studies in the report were completed before the requirement to register in ClinicalTrials.gov.