# References

1 Duval S, Tweedie R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. 2000 Jun;56(2):455–63. PMID: 10877304.10877304
2 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997 Sep 13;315(7109):629–34. PMID: 9310563.9310563
3 Harbord RM, Egger M, Sterne JA. A modified test for small-study effects in meta-analyses of controlled trials with binary endpoints. Stat Med. 2006 Oct 30;25(20):3443–57. doi: 10.1002/sim.2380. PMID: 16345038.16345038
4 Rucker G, Carpenter JR, Schwarzer G. Detecting and adjusting for small-study effects in meta-analysis. Biom J. 2011 Mar;53(2):351–68. doi: 10.1002/bimj.201000151. PMID: 21374698.21374698
5 Copas J, Shi JQ. Meta-analysis, funnel plots and sensitivity analysis. Biostatistics. 2000 Sep;1(3):247–62. doi: 10.1093/biostatistics/1.3.247. PMID: 12933507.12933507
6 Copas JB, Shi JQ. A sensitivity analysis for publication bias in systematic reviews. Stat Methods Med Res. 2001 Aug;10(4):251–65. PMID: 11491412.11491412
7 Hedges LV, Vevea JL. Estimating effect size under publication bias: small sample properties and robustness of a random effects selection model. Journal of Educational and Behavioral Statistics. 1996;21(4):299–332.
8 Laine C, Horton R, DeAngelis C, . Clinical trial registration: looking back and moving ahead. N Z Med J. 2007;120(1256):U2586. PMID: 17589554.17589554
9 Wood AJ. Progress and deficiencies in the registration of clinical trials. N Engl J Med. 2009 Feb 19;360(8):824–30. doi: 10.1056/NEJMsr0806582. PMID: 19228628.19228628
10 Zarin DA, Tse T, Sheehan J. The proposed rule for U.S. clinical trial registration and results submission. N Engl J Med. 2015 Jan 8;372(2):174–80. doi: 10.1056/NEJMsr1414226. PMID: 25539444.25539444
11 Chan AW, Hrobjartsson A, Haahr MT, . Empirical evidence for selective reporting of outcomes in randomized trials: comparison of protocols to published articles. JAMA. 2004 May 26;291(20):2457–65. doi: 10.1001/jama.291.20.2457. PMID: 15161896.15161896
12 Roest AM, de Jonge P, Williams CD, . Reporting Bias in Clinical Trials Investigating the Efficacy of Second-Generation Antidepressants in the Treatment of Anxiety Disorders: A Report of 2 Meta-analyses. JAMA Psychiatry. 2015 May 1;72(5):500–10. doi: 10.1001/jamapsychiatry.2015.15. PMID: 25806940.25806940
13 Vedula SS, Bero L, Scherer RW, . Outcome reporting in industry-sponsored trials of gabapentin for off-label use. N Engl J Med. 2009 Nov 12;361(20):1963–71. doi: 10.1056/NEJMsa0906126. PMID: 19907043.19907043
14 Vedula SS, Li T, Dickersin K. Differences in reporting of analyses in internal company documents versus published trial reports: comparisons in industry-sponsored trials in off-label uses of gabapentin. PLoS Med. 2013;10(1):e1001378. doi: 10.1371/journal.pmed.1001378. PMID: 23382656.23382656
15 Anderson ML, Chiswell K, Peterson ED, . Compliance with results reporting at ClinicalTrials.gov. N Engl J Med. 2015 Mar 12;372(11):1031–9. doi: 10.1056/NEJMsa1409364. PMID: 25760355.25760355
16 Viergever RF, Ghersi D. The quality of registration of clinical trials. PLoS One. 2011;6(2):e14701.21383991
17 Viergever RF, Karam G, Reis A, . The quality of registration of clinical trials: still a problem. PLoS One. 2014;9(1):e84727. doi: 10.1371/journal.pone.0084727. PMID: 24427293.24427293
18 Saunders C, Scott RE. Applying change management metaphors to a national e-Health strategy. Stud Health Technol Inform. 2014;206:62–9. PMID: 25365672.25365672
19 Balk E, Chung M, Lichtenstein A, . Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease. Evid Rep Technol Assess (Summ). 2004 Mar(93):1–6. PMID: 15133887.15133887
20 E B. Protocol: Omega 3 Fatty Acids and Cardiovascular Disease - Update. Rockville, MD: Agency for Healthcare Research and Quality 2015. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2060
21 Wang C, Chung M, Lichtenstein A, . Effects of omega-3 fatty acids on cardiovascular disease. Evid Rep Technol Assess (Summ). 2004 Mar(94):1–8. PMID: 15133888.15133888
22 Glanville JM, Duffy S, McCool R, . Searching ClinicalTrials.gov and the International Clinical Trials Registry Platform to inform systematic reviews: what are the optimal search approaches? J Med Libr Assoc. 2014 Jul;102(3):177–83. doi: 10.3163/1536-5050.102.3.007. PMID: 25031558.25031558
23 Jakobsen NK, Jensen LS, Kayser L. Collaborative efforts are needed to ensure proper knowledge dissemination of telemedicine projects. Dan Med J. 2014 Sep;61(9):A4896. PMID: 25186538.25186538
24 Bosch J, Gerstein HC, Dagenais GR, . n-3 fatty acids and cardiovascular outcomes in patients with dysglycemia. N Engl J Med. 2012 Jul 26;367(4):309–18. doi: 10.1056/NEJMoa1203859. PMID: 22686415.22686415
25 Damsgaard CT, Frokiaer H, Andersen AD, . Fish oil in combination with high or low intakes of linoleic acid lowers plasma triacylglycerols but does not affect other cardiovascular risk markers in healthy men. J Nutr. 2008 Jun;138(6):1061–6. PMID: 18492834.18492834
26 Leyva DR, Zahradka P, Ramjiawan B, . The effect of dietary flaxseed on improving symptoms of cardiovascular disease in patients with peripheral artery disease: rationale and design of the FLAX-PAD randomized controlled trial. Contemp Clin Trials. 2011 Sep;32(5):724–30. doi: 10.1016/j.cct.2011.05.005. PMID: 21616170.21616170
27 Rodriguez-Leyva D, Weighell W, Edel AL, . Potent antihypertensive action of dietary flaxseed in hypertensive patients. Hypertension. 2013 Dec;62(6):1081–9. doi: 10.1161/hypertensionaha.113.02094. PMID: 24126178.24126178
28 Kastelein JJ, Maki KC, Susekov A, . Omega-3 free fatty acids for the treatment of severe hypertriglyceridemia: the EpanoVa fOr Lowering Very high triglyceridEs (EVOLVE) trial. J Clin Lipidol. 2014 Jan–Feb;8(1):94–106. doi: 10.1016/j.jacl.2013.10.003. PMID: 24528690.24528690
29 Maki KC, Orloff DG, Nicholls SJ, . A highly bioavailable omega-3 free fatty acid formulation improves the cardiovascular risk profile in high-risk, statin-treated patients with residual hypertriglyceridemia (the ESPRIT trial). Clin Ther. 2013 Sep;35(9):1400–11.e1–3. doi: 10.1016/j.clinthera.2013.07.420. PMID: 23998969.23998969
30 Nodari S, Triggiani M, Campia U, . n-3 polyunsaturated fatty acids in the prevention of atrial fibrillation recurrences after electrical cardioversion: a prospective, randomized study. Circulation. 2011 Sep 6;124(10):1100–6. doi: 10.1161/circulationaha.111.022194. PMID: 21844082.21844082
31 Sakai T, Izumi M, Kumagai K, . Effects of a Foot Pump on the Incidence of Deep Vein Thrombosis After Total Knee Arthroplasty in Patients Given Edoxaban: A Randomized Controlled Study. Medicine (Baltimore). 2016 Jan;95(1):e2247. doi: 10.1097/md.0000000000002247. PMID: 26735531.26735531
32 Fuji T, Fujita S, Kawai YJ, . Efficacy and safety of edoxaban versus enoxaparin for the prevention of venous thromboembolism following total hip arthroplasty: STARS J-V. Thromb J. 2015;13:27. doi: 10.1186/s12959-015-0057-x. PMID: 25963358.26269694