# Methods

## Overview

The Brown EPC conducted a review of the relationship between n-3 FA intake and CVD outcomes, following Institute of Medicine standards and Agency for Healthcare Research and Quality (AHRQ) guidance. This review (hereafter, “original review”) did not include registry searches as part of the strategy to identify ongoing studies.

We searched ClinicalTrials.gov and ICTRP up to the last search date of the original review (6/8/2015) to identify additional studies not identified in the original review, or additional information on the design or results of studies included in the original review.

## Terminology

We use the term study to refer to the conducted research; a study may have one or more corresponding registry records in ClinicalTrials.gov or ICTRP registries, and these study results may be reported in the peer-reviewed literature as publications. A registry record provides basic information about a study’s design, and may include optional information on its results or publications associated with it. Studies identified through the registry search may have no associated publications; studies identified by the original report may have no records in a registry. A study was deemed to have been registered prospectively registration of data (defined here as registration of investigational studies prior to enrollment of the first patient or, for observational studies, prior to initial analyses.

## Registry Searches

Because the registry databases are not indexed, queries can include only text words. Thus, it was necessary to translate the search of the original review, which includes text words, as well as controlled-vocabulary (MeSH) terms, to a semantically equivalent query using the registry interfaces. In addition, the ClinicalTrials.gov search interface allows only for queries with a limited number of characters, and documentation on advanced searching options, such as truncation and adjacency searching, is sparse.^22, 23^ It is therefore better to search for “intervention” terms only.^22^ We conducted four queries in ClinicalTrials.gov whose union corresponded to the scope of the original search; we used an analogous search process in ICTRP. Appendix A includes the literature searches from the original report and the specific search strategies used in ClinicalTrials.gov and ICTRP.

## Screening, Data Extraction, and Data Management

Registry records were screened using the same approach employed in the original review (Appendix B). An evidence map comprised of registry records for eligible comparative and non-comparative studies was compiled, without minimum sample size or minimum follow up requirements. Basic study information (intervention, outcome, study design, sample size, and follow up duration) was recorded, noting if results were reported in the registry. Additional data was extracted from records that (1) included results and (2) met full eligibility criteria for the original report. These data include detailed study population data, the intervention details (i.e., n-3 FA type, dose, and duration), the reported outcomes, the numerical results, and on methodological items to assess the study risk of bias.

Data were extracted into the same customized forms developed and utilized for the original review in the Systematic Review Data Repository (SRDR) online system (http://srdr.ahrq.gov). Disagreements were resolved by discussion, with adjudication, when necessary, by the original report’s project lead.

## Analysis

Our study yield was categorized as follows: 1) registry record present, included in original review; 2) registry record present, not included in original review; and 3) no registry record, included in original review. Characteristics of studies found exclusively in the original review, in a registry database, or in both sources, were documented.

Study initiation date, study status (e.g., discontinued, in progress/ongoing) and, when available, rationale for discontinuation or delay were also documented.

We quantified the number of studies and publications included in the original review but not found to have a registry record. We focused on the value of results data identified via registry searches, and thus in our analyses, we highlight the congruence, or lack thereof, among data identified via the registry and found in the original report in light of additional study data identified via registry searches.

Studies included in the original review and found to have a registry record were reviewed for additional information pertinent to study design (if the registry record includes protocol information) or study findings (if the record includes results). Study design information extracted from the registry record was compared to that extracted from corresponding publications to assess if changes in the outcomes or analysis plan occurred.

Comparisons between registry records and publications were made with respect to 1) general design items used to inform risk of bias assessments and 2) the analysis plan of the eligible exposure-outcome relationships. The risk of bias of each study result in the original review was evaluated based on predefined questions (Appendix C). We assessed whether additional information identified in registry records changed the risk of bias assessments of the original review.

When study results were identified in registry records and in corresponding publications, we determined if the same outcome concepts were employed, and if yes, whether the results agree qualitatively (i.e. same direction). We also describe which outcome measures were reported in the registry record, the publication, or both.

Registry records of newly identified studies (not included in the original review) are summarized in narrative form and added to the original report’s evidence map. We applied the same risk of bias assessments as in the original review (Appendix C).

### Risk of Bias for the Evidence Base and Strength of Evidence

For outcomes with new data from the registries for specific n-3 FA comparisons, we reassessed the risk of bias of the evidence base and the strength of evidence using the same methodology used for the original report. We evaluated whether the additional data are likely to impact the findings of the study. We quantified this impact as a potential increase in total study population sample size (>20%), a change in the magnitude of outcome measures (20% change in estimate or a change in direction; ideally by meta-analysis), or a change in statistical significance (ideally by meta-analysis). Because meta-analyses were not conducted for most outcomes, we assessed whether the results from the new studies fall within the range of similar studies from the original report. If none of these conditions were met, the additional data were considered unlikely to directly impact the strength of evidence or the assessment of risk of bias for the evidence-base. All potential revisions to risk of bias and strength of evidence were discussed with the project lead of the original review. We describe and explain any changes to strength of evidence for any n-3 FA and outcome relationship.