# Discussion

## Summary of Findings

### Studies Identified via Registry Searches and Found in Original Review

Overall, 69 studies in 76 records identified through registry searches met full criteria for inclusion in the original report. Of these, 26 studies (in 27 registry records) were included in the original report (25 RCTs, 1 observational Study); 22 of these were found in ClinicalTrials.gov, 3 were found in ICTRP, and 1 was identified in both registries. Of the 26 studies in both sources, only 4 studies (in 4 records) included eligible results in the registry records. In general, the agreement between the registry record and the published paper was good when the information was given in both. A fifth record of a factorial study reported results, but no comparison between the n-3 FA and no n-3 FAs was reported in the record.

### Relevant Studies Identified via Registry Searches and Not Found in Original Review

Of the 69 studies in 76 records identified through registry searches that met full criteria for inclusion in the original report, 43 studies (in 49 records) were not found in the original review (42 randomized controlled trials and 1 Observational Study); 28 (57%) records in ClinicalTrials.gov and 21 records in ICTRP (43%). The completion status of studies described in the 49 records are as follows; completed n = 23, ongoing n= 10 and unknown status n=13. The study enrollment estimates for studies completed as of December 31, 2016 account for a projected 20,088 participants. An additional 145,275 participants were estimated to enroll in the remaining studies (ongoing and unknown status).

Reviewing the evidence map for the original report, we identified publications for seven of these studies, which did not meet inclusion/exclusion criteria for the original report. A single record yielded a new publication emanating from a study included in our original report. This new manuscript was published in the intervening time since the last update of the report search. Relevant results from this study were already identified in another publication and included in the report, the results in this newly identified manuscript were added to the report, but did not change the direction or magnitude of the results for those outcomes.

### Studies Included in the Original Review, with No Registry Record

The original report’s 98 studies included 61 randomized controlled trials in 82 articles and 37 longitudinal observational studies in 65 articles. Of these, we were unable to find a registry record for 72 studies (73%), including 36 randomized controlled trials (59%) and 36 longitudinal observational studies (97%).

## Process Limitations

Our study demonstrated that the EPC systematic review process was amenable to adaptions required for searching, abstracting, and analyzing registry search yields. We used a very broad search and screened out a large number of records, requiring more staff time than is spent on registry searching for typical EPC systematic reviews. More precise searching may reduce associated study costs and sensitivity of the search. In general, we found that registry records were easy to screen and extract – often easier than the resulting publications. Study design and interventions information was readily identifiable and in almost all cases matched that of the papers. However, the patient-level information (baselines and outcomes) was limited in scope and detail. The addition of individual patient data to these records could be very valuable.

Despite the relative ease of conducting registry searches in our study, the searches yielded no new information that would change our initial risk of bias or strength or evidence assessments. When available, study design, baselines, adverse events reporting, and results reported in the registry and publication typically aligned. Data identified via registry searches generally provided insufficient evidence to make judgments on specific risk of bias items. It was also difficult to draw any conclusions about publication bias based on our analyses.

Study outcomes information had highest number of discrepancies, potentially indication selective reporting bias. However, because many of these studies are relatively recent, it is also possible that information on these outcomes has not been published yet, but will be, indicating time lag, but not publication, bias

## Challenges to Incorporating Clinical Trial Registry Records into the Systematic Review Process

### Statistical Plans

We found no reporting of statistical design for any of the studies in our report. We reviewed Clinicaltrials.gov guidance to better understand this consistent pattern of non-reporting. Based on ClinicalTrials.gov guidance,^31^ statistical analysis plans (i.e., describing the analytical principles and statistical techniques to be employed in order to address the primary and secondary objectives, as specified in the study protocol or plan) and plans for missing data (i.e., to address situations where variables are reported as missing, unavailable, “non-reported,” uninterpretable, or considered missing because of data inconsistency or out-of-range results) are requested only for observational studies registered as patient registries.^31^ Our report included very few observational studies, and thus, statistical design reporting could not be assessed.

### Results

In September 2008, ClinicalTrials.gov added a results database to the registry record. Nevertheless, submission of results to a trial registry is not always required of investigators/authors. The Food and Drug Administration Amendments Act of 2007 (FDAAA; U.S. Public Law 110-85, Title VIII), mandates the posting of summary results data for certain trials in ClinicalTrials.gov.^32^ Of import, ICJME has stated that more detailed descriptions of trial results “beyond those included in ClinicalTrials.gov” may be considered prior publication, at the discretion of journal editors. Further, ICMJE does not require reporting of results for interventional clinical studies trials.^32^

Thus, a lack of results in a trial registry can be attributed to changes in the reporting requirements over time or a function of why investigators chose to register their study in the first place. Utilizing registry records to assess information bias pivot on both sponsor/investigator compliance with registration and sponsor/investigators perception of registry purpose, thus interpreting these omissions may unintentionally aggregate bias with inconsistent interpretation of the purpose, role and scope of ClinicalTrials.gov.

#### Next Steps

One way in which conducting a registry search is of value to a systematic review project is in identifying ongoing research, as well as gaps in knowledge, and facilitating prioritization of future research to reduce redundancy. Several of the studies not found in the original review but identified through registry searches were unfinished or in progress at the time of the search, these studies should be taken in to account when evaluating the state of the literature and calling for future research.