# Background and Objectives

Information biases, including publication bias, time-lag bias, selective outcome reporting bias, selective analysis bias, and fraud are major threats to the validity of systematic reviews. Systematic reviewers have pursued two methods approaches for dealing with information bias, namely, detecting (and possibly correcting results for) information bias based only on the identified studies (e.g., using funnel-plot based methods^1–4^ or various selection models^5–7^), and examining trial registries, surveying researchers, and perusing the grey literature to identify unpublished study results or ongoing studies. Arguably the best way to obtain empirical data on the prevalence and impact of information bias and perhaps to mitigate its impact is through clinical trial registries that include prospective registration of study protocols, as well as summarized results (e.g., the National Library of Medicine ClinicalTrials.gov registry and registry networks, such as International Clinical Trials Registry Platform [ICTRP]). Advocates of clinical trial registration emphasize the role of registry platforms to disseminate aggregated results to researchers, clinicians, and study participants. Registries enhance transparency by providing an inventory of studies that are in progress or have been completed.^8–10^

Empirical analyses of prospective registration of studies (defined here as registration of investigational studies prior to enrollment of the first patient or, for observational studies, prior to initial analyses) can inform on the time between study completion and publication, the number of unpublished studies, the fidelity of studies to registered protocols, and the congruence of study results between registry records and publications.^11–14^

This methods report assesses the value of searching ClinicalTrials.gov and ICTRP registry records in a systematic review of dietary supplements. Obtaining empirical data on studies of dietary supplements (e.g., fish oil) and interventions (e.g., increase of fish servings per week) in the context of a major clinical condition (e.g., cardiovascular disease [CVD]) adds to existing knowledge because the mechanisms through which information bias operates in this case may differ from studies of medications. The existing empirical research on information bias pertains almost exclusively to industry-sponsored drug, device, and biologic trials,^15–17^ despite the fact that 42 percent (88023) of all studies registered in ClinicalTrials.gov are indexed as “observational” or “behavioral/other intervention studies”. ^18^ Omega-3 fatty acids derive from both dietary supplements and consumption through a variety of plants and animal sources and these studies typically fall under these observational and other intervention studies. The inclusion of registry searches in our omega-3 review, will add to our understanding of the role of registry searching in non-industry, non-drug studies.

## Objectives

We examine the feasibility and added utility—in terms of impact on risk of bias and strength of evidence assessments—of comprehensive searches of the ClinicalTrials.gov and ICTRP registries to supplement the evidence identified in an ongoing systematic review update on omega-3 fatty acids (n-3 FA) and CVD outcomes conducted by the Brown Evidence-based Practice Center (EPC).^19–21^