# Appendix E Studies in Both the Report and Registry

Table E-1a Studies in both the report and registry

Table E-1b Studies in the registry only

Table E-2 Design Details Comparative Studies

Table E-3 Design Details: Observational studies

Table E-4 Outcomes Observational Studies

Table E-5 Baselines, Comparative Studies

Table E-6 Adverse effects/events

Table E-7 Risk of Bias, Comparative Studies

Table E-8 Risk of Bias, Observational Studies