# Appendix B Inclusion criteria: Effects of Omega-3 Fatty Acids on Cardiovascular Disease

P | - Healthy population without CVD or with low to intermediate CVD risk; - Adults without CVD but with high risk (e.g., diabetes, metabolic syndrome, hypertension, dyslipidemia, older age); - Adults with clinical CVD (e.g., MI, stroke, angina with confirming clinical tests); - Adults (≥18 y); ○ Include: Diabetes, Metabolic Syndrome, Hypertension, Dyslipidemia, existing CVD or symptoms; ○ Exclude: Selected for having non-CVD, non-DM related disease (eg, cancer, gastrointestinal disease, dialysis, chronic renal failure, rheumatic disease) or condition (eg, pregnancy)
I/C | - Intake:* EPA, DHA, EPA+DHA, SDA, and/or ALA quantified (does not need to be quantified in abstract, except Med diet); - Abstract needs to quantify the food or supplement (at a minimum); ○ Supplement, diet, or fortified foods (intervention or observational); ○ Minimum duration of intake: 1 year (clinical outcomes), 4 wk (BP, Lipids); ○ Exclude: Dose ≥6 g omega 3 (not total fish/plant oil); ○ Exclude: Adherence to Med diet or Med diet score (unless omega-3 quantified [in abstract]); ○ Exclude: Soy (or other) protein, soy isoflavones, other non-oil components; ○ Exclude: Weight loss diet (eg, fish/fish oil being used in a weight loss diet plan); ○ Exclude: Combination interventions of omega-3 & something else (eg, vitamin, E), but include if all participants have the same other intervention (eg, vit E vs vit E + n-3); ○ Exclude: Comparator is an active intervention (eg, pravastatin); - Biomarker:† Level measured (quantified); - Comparator must be lower dose/exposure omega-3 or no supplement etc. (eg, not vs. statin)
O | - Must mention CVD (or BP or lipids) in abstract; - All-cause mortality; - Cerebro/cardio-vascular disease (CVD) events:; ○ CVD-related (myocardial infarction, stroke) mortality; ○ non-fatal CVD events; ■ myocardial infarction, acute coronary syndrome, stroke/CVA, TIA, unstable angina, amputation 2° PVD, others; ○ coronary/cardiac disease; ○ peripheral vascular disease (PVD); ○ congestive heart failure (CHF); ○ pulmonary edema; ○ ventricular arrhythmia; ■ tachycardia, tachyarrhythmia, fibrillation, bradycardia, sudden death; ○ atrial fibrillation, supraventricular tachycardia; ○ cardiovascular invasive interventions (revascularization); ■ CABG (bypass), PCI (coronary angioplasty), vascular (arterial) surgery (carotid, peripheral); ■ Thrombolysis (eg, tPA to dissolve clot); - Major CVD risk factors (intermediate outcomes):; ○ blood pressure (new-onset hypertension, SBP, DBP, MAP); ○ key lipid values (HDL-cholesterol, LDL-cholesterol, triglycerides, LDL:HDL, TC:HDL); ■ Accept abstracts of LDL (or other lipid) particle size; - Adverse events (eg, bleeding, gastrointestinal), only from intervention studies of supplements
D | - RCTs (all outcomes); - Randomized cross-over (XO) studies (blood pressure and lipids, adverse events); - Nonrandomized comparative studies, prospective or retrospective longitudinal (clinical outcomes, adverse events): measure of n-3 intake/exposure must have occurred ≥1 year prior to measurement of events; - Prospective or retrospective cohort (single group) studies, where groups are compared based on n-3 FA intake or intake biomarker values (clinical outcomes) : measure of n-3 intake/exposure ≥1 year prior to events; - Nested case-control studies (clinical outcomes) (case control study done within a prospective study): measure of n-3 intake/exposure must have occurred ≥1 year prior to measurement of events; - Exclude: cross-sectional (exposure and outcome measured at same time), case control (retrospective); - UNCLEAR: observational studies for blood pressure and lipids [tag as maybe]; - Timing; ○ Clinical outcomes, including new-onset hypertension: ≥1 year follow-up; ○ Intermediate outcomes (blood pressure and lipids): ≥1 month follow-up; ○ Adverse events: no minimum follow-up; - Minimum sample sizes (per 2004 protocols*); ○ Clinical outcomes: RCT/nRCS: no minimum; Longitudinal single group N≥100; ○ BP/Lipids (RCT): N≥x (no minimum for now); ○ Adverse events: N≥100; - Tag and REJECT trial protocols/designs