# Summary and Conclusion

In this paper, we provided cases that highlight (1) systematic reviews of observational evidence included to fill gaps in RCT evidence and (2) systematic reviews of observational studies as well as primary observational studies that demonstrate strength of evidence domains as described in the AHRQ Methods Guide. These cases are meant to inform the decision to include/exclude observational studies and how to evaluate their strength of evidence in systematic reviews.

In general, we can be more confident in the results of observational studies when design or analyses have minimized the potential for common sources of bias, results are precise and consistent, and when we observe a large strength of association, a dose-response association, or plausible confounding very likely to decrease the observed effect. Importantly, of all the examples of strong observational studies solicited for this project, we did not identify any additional strength of evidence factors not already included in the AHRQ Methods Guide, providing support for the comprehensiveness of this and other similar guidance. These strength of evidence domains are often specific to clinical topics and individual study factors warrant careful consideration before upgrading an observational study body of evidence, as noted in the current AHRQ EPC Methods Guide on strength of evidence;2 however, our case examples show instances where studies should not be automatically excluded because they are not RCTs. Further identification and description of cases where observational studies have contributed to higher strength of evidence ratings in a systematic review of health care interventions would be beneficial. Future research could expand upon these case examples to include demonstrations of how to conduct risk of bias assessment and strength of evidence ratings for observational studies.