# References

1 Norris S, Atkins D, Bruening W, et al. Selecting observational studies for comparing medical interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No.10(11)-EHC063-EF. Rockville MD. Agency for Healthcare Research and Quality. 2010. [pmid: 21433401].
2 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions – AHRQ and the Effective Health Care Program: An Update. Draft, 2012. Final in Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
3 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
4 Viswanathan M, Mohammed AT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville MD. Agency for Healthcare Research and Quality. March. 2012:5.
5 Norris SL, Moher D, Reeves BC, et al. Issues relating to selective reporting when including non-randomized studies in systematic reviews on the effects of healthcare interventions. Res Synth Methods. 2013;4(1):36-47.
6 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0. [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
7 Treadwell JR, Singh S, Talati R, et al. A Framework for“ Best Evidence” Approaches in Systematic Reviews. AHRQ Publication No. 11-EHC046-EF. Rockville MD. Agency for Healthcare Research and Quality. June. 2011. [pmid: 21834173].
8 Schünemann HJ, Tugwell P, Reeves BC, et al. Non-randomized studies as a source of complementary, sequential or replacement evidence for randomized controlled trials in systematic reviews on the effects of interventions. Res Synth Methods. 2013;4(1):49-62.
9 Reeves BC, Deeks JJ, Higgins JP, et al. Chapter 13: Including non-randomized studies. Higgins JPT, G S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.1. The Cochrane Collaboration. 2008;5.
10 Higgins JPT, Ramsay C, Reeves BC, et al. Issues Issues relating to study design and risk of bias when including non-randomized studies in systematic reviews on the effects of interventions. Res Synth Methods. 2013;4(1):12-25.
11 Viswanathan M, Visco AG, Hartmann K, et al. Cesarean delivery on maternal request. Evid Rep Technol Assess. 2006;133:1-138. [pmid: 17627329].
12 McDonagh M, Peterson K, Carson S, et al. Class Review: Atypical Antipsychotic Drugs. Oregon Evidence-based Practice Center. 2005.
13 McDonagh M, Peterson K, Carson S, et al. Drug Class Review: Atypical Antipsychotic Drugs: Update 1. Oregon Evidence-based Practice Center. 2006.
14 Warren Z, Veenstra-VanderWeele J, Stone W, et al. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
15 Taylor JL, Dove D, Veenstra-VanderWeele J, et al. Interventions for Adolescents and Young Adults With Autism Spectrum Disorders. Comparative Effectiveness Review No. 65. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 12-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012.
16 Penson DF, Krishnaswami S, Jules A, et al. Evaluation and Treatment of Cryptorchidism. Comparative Effectiveness Review No. 88. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 13-EHC001-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
17 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. 2008.
18 Ray WA. Evaluating medication effects outside of clinical trials: new-user designs. Am JEpidemiol. Nov. 1. 2003;158(9):915-20. [pmid: 14585769].
19 Schneeweiss S, Rassen JA, Glynn RJ, et al. High-dimensional propensity score adjustment in studies of treatment effects using health care claims data. Epidemiol. 2009;20(4):512-22. [doi: 10.1097/EDE.0b013e3181a663cc]. [pmid: 19487948].
20 Rassen JA, Schneeweiss S. Using high-dimensional propensity scores to automate confounding control in a distributed medical product safety surveillance system. Pharmacoepidemiol Drug Saf. 2012;21:41-9. [pmid: 22262592].
21 Hannan EL. Randomized clinical trials and observational studies guidelines for assessing respective strengths and limitations. JACC: Cardiovasc Interv. 2008;1(3):211-7. [pmid: 19463302].
22 Wells GA, Shea B, Higgins J, et al. Checklists of methodological issues for review authors to consider when including non-randomized studies in systematic reviews. Res Synth Methods. 2013;4(1):63-77.
23 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
24 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. Winchester, England. 2003;7(27).
25 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. 2012;65(2):163-78. [pmid: 21959223].
26 Thompson DC, Rivara FP, Thompson R. Helmets for preventing head and facial injuries in bicyclists. Cochrane Database of Syst Rev. 2000;(2):CD001855. [pmid: 10796827].
27 Sjöström L, Narbro K, Sjöström CD, et al. Effects of bariatric surgery on mortality in Swedish obese subjects. N Engl J Med. 2007;357(8):741-52. [pmid: 17715408].
28 Neglia JP, Robison LL, Stovall M, et al. New primary neoplasms of the central nervous system in survivors of childhood cancer: a report from the Childhood Cancer Survivor Study. J Natl Cancer Inst. 2006;98(21):1528-37. [pmid: 17077355].
29 Darby SC, Ewertz M, McGale P, et al. Risk of ischemic heart disease in women after radiotherapy for breast cancer. N Engl J Med. 2013;368(11):987-98. [pmid: 23484825].