# Results

## Compilation of Potential Questions for Item Bank

During phase 1 of the project, we reviewed earlier instruments that had been used for evaluating the quality or risk of bias of observational studies and compiled 1,492 items that were available through the published literature and 84^22-24,26-105^ of the 90 Agency for Healthcare Research and Quality (AHRQ)-sponsored systematic reviews that had been completed at the start of the project (2007); the remaining 6^25,34,106-109^ were either solely focused on RCTs or on evaluation of genetic tests. All items that we collected were categorized into the 12 quality domains (and related subdomains) identified in Deeks et al.10 We further evaluated the comprehensiveness of the items gathered through that phase by comparing items systematically with those included in other instruments identified through our searches (e.g., Downs and Black15 and Newcastle Ottawa14) or provided to us by our TEP.13,16,109-112 The intent of casting such a wide net was to ensure a comprehensive set of items.

Many of the 1,492 items were completely or partially redundant. The study team selected 60 items for measuring each of the included domains based on readability and comprehensiveness of instruction (Figure 1). During the development process, we reviewed items and responses and modified wording to ensure that critical domains were represented and to improve readability.

Figure 1 Disposition of questions for item bank

Figure 1 shows a flow chart for the disposition of questions for the item bank.

During phase 2 of the project, we crafted explanatory text that can be used by systematic review project directors to individualize the pool of items chosen for a review and assist project directors and abstractors in standardizing item interpretation.

### Face Validity Testing

We conducted face validity testing with TEP members. The intent of face validity testing was to ensure that the bank comprehensively included items that could evaluate issues of concerns within each of the methods domains relevant for the evaluation of observational studies and did not include items that the TEP concluded would only be relevant for other study designs. Face validity testing on a 60-item version of the item bank, including instructions for project directors and abstractors, resulted in the elimination of 16 questions. Items eliminated were considered outside scope of the item bank or not relevant to systematic reviews. Two questions were added and several questions were subsumed into other questions (See Figure 1 and Table 3 for details concerning the disposition of specific questions.).14,15

Table 3 Validity and reliability results and disposition of questions

Methods Domain | Methods Subdomain and Assessment Question | Dimension of Bias or Precision Evaluated | Face Validity and Cognitive Testing/Experienced Reviewer Results | Content Validity Results by Study Design Type: Percentage of Experts Who Considered the Question Essential for Evaluating Bias | Interrater Reliability Results: Mean Agreement (range) AC1 Statistic (conditional confidence interval) | Disposition Rationale
Background/ context | Provision of background information: Is the study presented in the context of clinical practice and policy? | None, study descriptor | Face validity results: Retained Cognitive testing/experienced reviewer results: Eliminated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: relevance to systematic reviews This question was deleted based on cognitive testing/expert review because it was determined to be unnecessary for evaluating bias for a systematic review.
Background/ context | Background/question clearly stated: Is the hypothesis/aim/ objective of the study described? | None, study descriptor | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = -0.14 Case-control: CVR = 0.14 Case series: CVR = -0.43 | Interrater reliability results: 94% (83%–100%) 0.88 (0.78–0.98) | Deleted: relevance to systematic reviews This question was deleted because as a study descriptor (reporting of information), content validity testing found the question to generally not be essential for evaluating bias. The question is also unlikely to distinguish risk of bias differences between studies because mean agreement between raters during interrater reliability testing was quite high (94%; almost all responded, “yes”).
Background/ context | Rationale/theoretical framework: Was the intervention/ exposure considered within the context of a theoretical framework or causal pathway? | Selection bias: confounding | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.43 Cross-sectional: CVR = -0.71 Case-control: CVR = -0.43 Case series: CVR = -0.43 | Interrater reliability results: 52% (42%–83%) 0.10 (-0.01–0.22) | Deleted: relevance to evaluating bias and precision Content validity testing found that the question was not essential across all study designs. The question directly measures reporting and only indirectly suggests risk of bias through failure to account for alternative explanations. It also performed poorly during interrater reliability testing.
Sample definition and selection | Retrospective/prospe ctive: Is the study design prospective, retrospective, or mixed? | Reporting question related to selection bias; performance bias; detection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.71 Cross-sectional: CVR = -1 Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 88% (50%–100%) 0.78 (0.56–1.00) | Retained, considered a second-tier question Content reviewers generally supported retaining this question, particularly in relation to evaluating cohort studies and it performed well in interrater reliability testing. However, the study team acknowledges that increasingly, experts do not necessarily consider one study design to be inherently better than another (see Cochrane Collaboration guidance and Rothman, Greenland & Lash (2008)). Therefore, this is not considered to be a critical question.
Sample definition and selection | Retrospective/prospe ctive: Is the study design appropriate for answering the study's research questions? | None, overall study quality | Face validity results: Retained Cognitive testing/experienced reviewer results: Eliminated | Cohort: CVR = NA Cross-sectional: CVR = NA Case-control: CVR = NA Case series: CVR = NA | Face validity results: NR Interrater reliability results: NR | Deleted: relevance to systematic reviews This question was deleted based on cognitive testing/expert review because it was considered to be relevant for evaluating bias for a systematic review.
Sample definition and selection | Inclusion/exclusion criteria: Are the inclusion/exclusion criteria clearly stated? | Reporting question, related to selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 1.0 Cross-sectional: CVR = 0.43 Case-control: CVR = 1.0 Case series: CVR = 0.71 | Interrater reliability results: 72% (42%–100%) 0.46 (0.28–0.65) | Retained, additional instruction added Interrater reliability was lower in part because there was disagreement between raters concerning whether the correct response was “all” or “partially.” We added additional instructions to the PI concerning specification of criteria.
Sample definition and selection | Inclusion/exclusion criteria: Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants? | Information bias | Face validity: Not evaluated, added after Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = -0.14 Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 69% (50%–100%) 0.40 (0.24–0.57) | Retained: additional instruction added during the development process. Interrater agreement varied across studies and so we added direction to the PI to specify important criteria that abstractors need to consider.
Sample definition and selection | Inclusion/exclusion criteria: Did the study apply inclusion/exclusion criteria uniformly to all comparison groups? | Selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 1.0 Cross-sectional: CVR = NA Case-control: CVR = 1.0 Case series: CVR = NA | Interrater reliability results: 61% (33%–92%) 0.30 (0.13–0.46) | Retained Question wording was changed during development process from negative to positive for consistency with majority of other questions. Additional instruction was added to address confusion expressed among interrater reliability raters in relation to single-armed studies.
Sample definition and selection | Inclusion/exclusion criteria: Was the strategy for recruiting participants into the study described? | Reporting question, related to selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = NA Case-control: CVR = NA Case series: CVR = NA | Interrater reliability results: 68% (42%–-92%) 0.37 (0.22–0.53) | Deleted: subsumed in another question Other questions that incorporate this issue as a response category (relevant to reporting) are included in the tool, and so this question considered unnecessary. Also, rater agreement was fairly low, primarily because raters did not agree on the level of detail needed to adequately respond.
Sample definition and selection | Inclusion/exclusion criteria: Did the strategy for recruiting participants into the study differ across study groups? | Performance bias | Face validity: Not evaluated Cognitive testing/ experienced reviewer: Not evaluated, added after | Cohort: CVR = 0.71 Cross-sectional: CVR = NA Case-control: CVR = Not evaluated Case series: CVR = NA | Interrater reliability results: 70% (50%–92%) 0.41 (0.27–0.55) | Retained Emphasis changed from negative to positive to be consistent with most other questions; additional detail added to one of the response categories. Clarified in not applicable response category that the question would not apply to studies with one arm.
Sample definition and selection | Power and sample size: Did the authors report conducting a power analysis or some other basis for determining the adequacy of study group sizes for the primary outcome(s) being abstracted? | Reporting question, related to precision | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = -0.71 Case-control: CVR = -0.71 Case series: CVR = -0.43 | Interrater reliability results: 80% (58%– 100%) 0.57 (0.42–0.72) | Deleted: subsumed in another question Content validity ratings supported deleting across study types because it is a measure of precision rather than bias. Because it is a reporting question, it was not considered valuable for evaluating precision although it performed reasonably well in terms of interrater reliability. The tool retains other, more direct questions for evaluating precision.
Sample definition and selection | Power and sample size: Was the sample size sufficiently large to detect a clinically significant difference of 5% or more between groups in at least one primary outcome measure? | Precision | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.14 Case series: CVR = -0.43 | Interrater reliability results: 55% (33%–75%) 0.14 (-0.02–0.30) | Retained: additional direction provided to the PI. We have retained this question to address this aspect of precision because it may be important to some reviews. We acknowledge that establishing standards to answer the question can be difficult. Interrater reliability was low for this question, and so we added additional directions for the PI.
Sample definition and selection | Baseline characteristics described: Are key characteristics of study participants described? | Reporting question, related to selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.71 Case series: CVR = 0.43 | Interrater reliability results: 68% (42%–92%) 0.44 (0.28–0.60) | Deleted: subsumed in another question This question was deleted because it is accounted for in responses to questions about controls for differences in baseline characteristics that directly measure bias. Also, raters had difficulty determining which characteristics needed to be described.
Interventions/ Exposure | Clear specification: What is the level of detail in describing the intervention or exposure? | Reporting question, related to performance bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.43 Case series: CVR = 0.14 | Interrater reliability results: 61% (42%–100%) 0.34 (0.19–0.50) | Retained; information added to the PI instructions and response categories Interrater reliability agreement was low, partially because raters differed in their evaluation of the level of detail that they considered sufficient. To address this, additional instruction was added for the PI to specify criteria for abstractors.
Interventions/ Exposure | Clear specification: What is the level of detail in describing the test reference standard? | Reporting question related to performance bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: scope This question was deleted based on face validity evaluation by the Technical Expert Panel. It was decided that this item bank would not be used to evaluate diagnostic testing.
Interventions/ Exposure | Clear specification: What is the level of detail in describing the intervention protocol? | Reporting question related to performance bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel because it was determined to be unnecessary for evaluating bias for a systematic review. The reporting element of this question is incorporated within another question that asks about deviation from protocol.
Interventions/ Exposure | Concurrent/concomit ant treatment: Are concurrent or concomitant treatments described? | Reporting question, related to performance bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.43 Case series: CVR = 0.14 | Interrater reliability results: 58% (33%–92%) 0.23 (0.07–0.40) | Deleted: subsumed in another question This question was deleted because it was determined by the study team to be unnecessary. The reporting element of this question is incorporated within another question that asks about controlling for concurrent treatment. Also, the question did not perform well because raters had difficulty consistently determining which characteristics needed to be described.
Interventions/ Exposure | Description of care for comparison groups: Is usual clinical care described? | Reporting question, related to performance bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = -0.14 Case-control: CVR = -0.14 Case series: CVR = -0.43 | Interrater reliability results: 59% (33%–100%) 0.26 (0.07–0.45) | Deleted: overlap This question was deleted because content validity evaluation generally found it to not be essential. Also, agreement between raters was low which may be related to an inability to distinguish usual clinical care from concurrent treatment and to determine the level of detail necessary to report.
Outcomes | Clear specification: Are the potential outcomes, including harms, pre-specified by the researchers? | Reporting bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 66% (33%–100%) 0.39 (0.23–0.56) | Retained: additional information added to the question and instruction added for the PI Question was edited to address content expert and rater concerns that the question needed more instruction for case-control and that harms need not always be pre-specified. Some raters may have had difficulty answering this question because outcomes of interest were not specified.
Outcomes | Clear specification: Are the primary outcomes described? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel which concluded that it was unnecessary for evaluating bias for a systematic review. The response to this question is included as a response to a question on assessment of outcomes.
Outcomes | Clear specification: Are the secondary outcomes described? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel which concluded that it was unnecessary for evaluating bias for a systematic review. The response to this question is included as a response to a question on assessment of outcomes.
Outcomes | Clear specification: Are harms or anticipated adverse events described? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel which concluded that it was unnecessary for evaluating bias for a systematic review. The response to this question is included as a response to a question on assessment of outcomes.
Outcomes | Objective and/or reliable: Do the researchers report the time points for measurement of the primary outcomes? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel and the study team that this question should be addressed as part of the more general question on clear specification of outcomes.
Outcomes | Objective and/or reliable: Do the researchers report the time points for measurement of the secondary outcomes? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel and the study team that this question should be addressed as part of the more general question on clear specification of outcomes.
Creation of treatment groups | Random allocation: If participants are randomized, were appropriate randomization methods used? | Selection bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: scope This question was deleted based on expert input through face validity evaluation by the Technical Expert Panel that the evaluation of randomization was not necessary for observational studies.
Creation of treatment groups | Clear specification: Are the criteria for assignment to study groups described? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel which concluded that it was unnecessary for reporting bias for a systematic review. Consideration of groups is evaluated through the question on uniform application of criteria to comparison groups.
Creation of treatment groups | Allocation Is assignment made to study groups randomly? | Selection bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: scope This question was deleted based on expert input through face validity evaluation by the Technical Expert Panel that the evaluation of randomization was not necessary for observational studies.
Creation of treatment groups | Allocation Is an explicit case/comparison definition reported? | Reporting question related to selection bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer results: NR | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was considered unnecessary because an evaluation of the choice of the case and comparison groups is accomplished through the question clear statement of inclusion/exclusion criteria.
Creation of treatment groups | Allocation Is the selection of the comparison group appropriate? | Selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 1.0 Cross-sectional: CVR = NA Case-control: CVR = Not evaluated Case series: CVR = NA | Interrater reliability results: 69% (42%–100%) 0.42 (0.25–0.59) | Retained, additional information added to help clarify the question. Depending on the review, appropriate may take into account feasibility or ethics. Content experts considered this question to be essential for cohort studies.
Creation of treatment groups | Any attempt to balance: Any attempt to balance the allocation between the groups? | Selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = NA Case-control: CVR = Not evaluated Case series: CVR = NA | Interrater reliability results: 63% (42%–92%) 0.32 (0.17–0.46) | Retained: additional clarifying information added to response categories and additional instruction provided to PI We combined “no” and “cannot determine” response categories because there is no appreciable distinction between the categories and raters could not distinguish between the two in a consistent manner. In response categories, we also accounted for designs that address differences between groups through post-hoc approaches such as multivariate analysis.
Creation of treatment groups | Clear specification: Have researchers reported the possibility of participants having received an unintended intervention? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel which concluded that it was unnecessary for reporting bias for a systematic review. Contamination, as it relates to performance bias is evaluated more directly through a subsequent question concerning unintended exposure.
Creation of treatment groups | Contamination Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results? | Performance bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = -0.14 Case series: CVR = -0.43 | Interrater reliability results: 62% (42%–92%) 0.34 (0.21–0.48) | Retained: Response categories edited based on inconsistencies in responses and comments obtained during interrater reliability testing. We added a response category of “partially” and combined “no” and “don't know.” The “don't know” response would identify instances of insufficient reporting.
Creation of treatment groups | Contamination Did variation from the study protocol compromise the conclusions of the study? | Performance bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = Not evaluated Case-control: CVR = -0.14 Case series: CVR = -0.14 | Interrater reliability results: 51% (42%–67%) 0.21 (0.15–0.27) | Retained: Edited to clarify that the protocol of interest is the study protocol and not an analytic protocol. The question was respecified so that it is written in relation to intervention studies only.
Creation of treatment groups | Contamination: Is adherence to the protocol reported? | Reporting question related to performance bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on face validity evaluation by the Technical Expert Panel which concluded that it was unnecessary for reporting bias for a systematic review. The answer to this question is incorporated in a response to the question on whether the execution of the study varied from the protocol.
Blinding | Blind administration Were study participants blinded to their group assignment? | Detection bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: scope This question was deleted based on expert input through face validity evaluation by the Technical Expert Panel that this was not relevant for evaluating bias in observational studies.
Blinding | Blind administration: Are those administering the intervention blinded to the study assignment or exposure status of participants? | Detection bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: scope This question was deleted based on expert input through face validity evaluation by the Technical Expert Panel that this was not relevant for evaluating bias in observational studies.
Blinding | Blind outcome assessment Were the outcome assessors blinded to the intervention or exposure status of participants? | Detection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = Not evaluated Case-control: CVR = Not evaluated Case series: CVR = 0.43 | Interrater reliability results: 69% (50%–100%) 0.46 (0.28–0.64) | Retained: Edited to clarify that there may be instances in which the outcome assessment cannot be blinded. Based on rater lack of agreement, we clarified that the response “not applicable” applies to studies in which an assessor cannot be blinded and provided clarifying instructions for the PI.
Soundness of information | Source of information about interventions/ exposure Are interventions/ exposures assessed using valid and reliable measures, implemented consistently across all study participants? | Information bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.71 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.43 Case series: CVR = 0.14 | Interrater reliability results: 82% (42%–100%) 0.65 (0.48–0.82) | Retained: Additional instructions provided for the PI We added instruction for the PI concerning criteria for evaluating what may be valid and reliable measures.
Soundness of information | Source of information re outcomes Are primary outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Information bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.71 Cross-sectional: CVR = 0.71 Case-control: CVR = 0.71 Case series: CVR = 0.14 | Interrater reliability results: 93% (75%–100%) 0.87 (0.76–0.98) | Retained: Additional instructions provided for the PI We added instruction for the PI concerning criteria for evaluating what may be valid and reliable measures, consistent with the edits for the item concerning interventions/exposures.
Follow-up | Equality of length of follow-up for participants In cohort studies, is the length of follow-up different between the groups, or in case-control studies, is the time period between the intervention/exposu re and outcome the same for cases and controls? | Attrition bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.71 Cross-sectional: CVR = NA Case-control: CVR = 0.71 Case series: CVR = NA | Interrater reliability results: 57% (42%–92%) 0.19 (0.05–0.33) | Retained: Question and response categories edited We changed the wording of the question from “different” to “same” for all groups, based on comments from raters that the question was confusing. We combined “no” and “don't know,” categories, which we thought equivalent.
Follow-up | Length of followup adequate Is the length of time following the intervention/exposu re sufficient to support the conclusions of the study regarding primary outcomes? | Attrition bias | Face validity results: Asked as one question concerning all outcomes, Retained and changed to 2 questions (primary outcomes and harms) Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = NA Case-control: CVR = 0.71 Case series: CVR = 0.43 | Interrater reliability results: 58% (33%–83%) 0.27 (0.16–0.38) | Retained: Edited for clarity; benefits and harms evaluation combined into one question. Based on rater uncertainty, we added additional instruction to PIs to specify outcomes. Benefit and harm outcomes were combined into one question. The question was taken out of the context of what study authors may have concluded, and instead, concerns whether the reviewer considers the follow-up period sufficient to support the results as measured
Follow-up | Length of followup adequate Is the length of time following the intervention/exposu re sufficient to support the conclusions of the study regarding harms? | Attrition bias | Face validity results: Asked as one question concerning all outcomes, retained and changed to 2 questions (primary outcomes and harms) Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = NA Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 54% (33%–83%) 0.18 (0.06–0.30) | Deleted: subsumed in another question We deleted this question to create one question concerning sufficient follow-up for both benefits and harms. The PI will need to specify sufficiency of follow-up for specific outcomes if it differs across outcomes.
Follow-up | Completeness of follow-up Are all participants in all study arms accounted for in follow-up? | Attrition bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question We deleted this question following face validity evaluation by the Technical Expert Panel. We determined that this question would be answered by the question that requires the abstractor to determine the attrition rate.
Follow-up | Completeness of follow-up Did attrition from any group exceed [x] percent? | Attrition bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = NA Case-control: CVR = -0.43 Case series: CVR = Not evaluated | Interrater reliability results: 51% (42%–67%) 0.13 (0.08–0.18) | Retained: Additional instruction provided. While this was not a good performing question based on content validity or interrater reliability testing, due to our concerns about evaluating attrition bias, we are retaining this question. We acknowledge that it can be a difficult question to answer; abstractors were particularly unsure about how to evaluate retrospective studies.
Follow-up | Completeness of follow-up Did attrition differ between groups by more than 20 percentage points? | Attrition bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = NA Case-control: CVR = -0.14 Case series: CVR = NR | Interrater reliability results: 58% (42%–83%) 0.23 (0.10–0.37) | Retained: Additional instruction provided We provided additional instruction concerning how to evaluate retrospective studies.
Analysis comparability | Analysis of baseline comparability Are baseline characteristics similar between groups? | Selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = NA Case-control: CVR = 0.14 Case series: CVR = NA | Interrater reliability results: 54% (33%–92%) 0.22 (0.08–0.35) | Deleted: subsumed in another question This issue is evaluated through the question that concerns whether baseline differences are addressed (controlled for) through the analysis
Analysis comparability | Analysis of baseline comparability Does the analysis control for baseline differences between groups? | Selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = NA Case-control: CVR = 0.43 Case series: CVR = NA | Interrater reliability results: 65% (33%–100%) 0.33 (0.14–0.51) | Retained: Several response categories were modified for greater clarity.
Analysis comparability | Identification of prognostic factors (effect modifiers and confounders) Does the study identify important confounding variables and effect modifiers? | Reporting question related to selection bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.71 Case series: CVR = -0.14 | Interrater reliability results: 62% (42%–92%) 0.32 (0.19–0.45) | Deleted: subsumed in another question The answer to this question is part of the response category to a subsequent question on whether confounding variables are accounted for in the design.
Analysis comparability | Identification of prognostic factors (effect modifiers and confounders) Are confounding variables assessed using valid and reliable measures, implemented consistently across all study participants? | Information bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.14 Case series: CVR = -0.14 | Interrater reliability results: 55% (33%–92%) 0.20 (0.04–0.37) | Retained: Question and response categories edited to improve clarity This question performed inconsistently across studies and so we added direction to help ensure that adequate specification is provided by the PI.
Analysis comparability | Case-mix adjustment: Were the important confounding and modifying variables taken into account in the design and analysis? | Selection bias: confounding | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = -0.14 Case-control: CVR = 0.43 Case series: CVR = -0.71 | Interrater reliability results: 65% (33%–83%) 0.35 (0.21–0.49) | Retained: Question and response categories edited to improve clarity This question performed inconsistently across studies and so we added direction to help ensure that adequate specification is provided by the PI.
Analysis outcome | Intention-to-treat analysis Is the analysis conducted on an intention-to-treat (ITT) basis? | Attrition bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = NA Case-control: CVR = NA Case series: CVR = NA | Interrater reliability: Not evaluated | Deleted: subsumed in another question The more important question concerning the evaluation of the impact of loss to follow-up is evaluated through the next question.
Analysis outcome | Intention-to-treat analysis Is the impact of loss to follow-up assessed? | Attrition bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 60% (42%–83%) 0.26 (0.14–0.39) | Retained: Response categories were edited to improve clarity and address inconsistencies across study raters.
Analysis outcome | Appropriate analytic methods Are findings for all primary outcomes reported? | Reporting bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.43 Case series: CVR = 0.43 | Interrater reliability results: 79% (50%–100%) 0.63 (0.50–0.76) | Retained: Emphasis of the question changed from reconciliation between what authors said they would and did do to what could be reasonably expected. The emphasis of this question was changed to more directly evaluate whether any important findings were omitted from the publication, in contrast to what the study authors say they intended to evaluate. The PI will need to specify primary outcomes for abstractors.
Analysis outcome | Clear specification Are the statistical approaches for analyzing the data reported? | Reporting question related to reporting bias | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on Technical Expert Panel member face validity review because it was determined to be unnecessary for evaluating bias for a systematic review. The evaluation of the precision of estimate based on the study methodology is evaluated through a subsequent question concerning the appropriateness of the methods used in the study.
Analysis outcome | Appropriate analytic methods Are the statistical methods used to assess the primary outcomes appropriate to the data? | Precision | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.71 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.71 Case series: CVR = 0.14 | Interrater reliability results: 66% (42%–92%) 0.39 (0.28–0.51) | Retained: Expanded to more comprehensively capture assessment of primary outcomes to include reporting of random variability This question was combined with a subsequent question concerning reporting of the random variability of the outcome.
Analysis outcome | Appropriate analytic methods Have all important harms or adverse events that may be a consequence of the intervention/exposu re been reported? | Reporting bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = -0.14 Case series: CVR = 0.14 | Interrater reliability results: 64% (42%–83%) 0.33 (0.22–0.45) | Retained: Emphasis of the question changed from reconciliation between what authors said they would and did do to what could be reasonably expected. The emphasis of this question was changed to more directly evaluate whether any important findings were omitted from the publication, in contrast to what the authors say they intended to evaluate. To reduce the abstractor burden, the PI needs to specify what the abstractors should be looking for.
Analysis outcome | Appropriate analytic methods Are the statistical methods used to assess the main harm or adverse event outcomes appropriate to the data? | Precision | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.43 Case series: CVR = -0.14 | Interrater reliability results: 66% (50%–83%) 0.31 (0.21–0.41) | Retained: Expanded to include reporting of random variability to more comprehensively capture assessment of harms: parallels question concerning methods used to report benefits. This question was combined with a subsequent question concerning reporting of the random variability of the outcome.
Analysis outcome | Appropriate analytic methods For cohort studies only, if the outcome has a greater than 10 percent prevalence, is the risk ratio and relative risk calculated directly (not using logistic regression)? | Precision | Face validity results: Retained Cognitive testing/experienced reviewer results: Eliminated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: subsumed in another question This question was deleted based on expert review/cognitive interviews because it was determined that the information is captured through the more general questions concerning appropriate analytic methods.
Analysis outcome | Appropriate analytic methods: Does the study appropriately report estimates of the random variability in the data for the primary outcomes? | Reporting question related to precision | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.43 Cross-sectional: CVR = 0.43 Case-control: CVR = 0.43 Case series: CVR = 0.43 | Interrater reliability results: 66% (42%–92%) 0.38 (0.23–0.53) | Deleted: subsumed in another question Information that would have been obtained through this question can be captured through other analytic questions.
Interpretation | Appropriately based on results Are conclusions supported by results with possible biases and limitations taken into consideration? | Not Applicable, overall study quality | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = 0.14 Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 66% (42%–92%) 0.32 (0.17–0.48) | Retained: edited to capture the abstractor's evaluation of the overall risk of bias and precision of the study and not what was intended by the study's authors. This question provides the abstractor's evaluation of the risk of bias and precision of the study overall. The wording of the question was changed for greater simplicity and understanding.
Interpretation | Interpretation in context Are results interpreted appropriately based on study design and statistical analysis? | Not applicable, overall study quality | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: relevance to systematic reviews Based on expert review, this question was determined to not be relevant for the purposes of conducting a systematic review.
Interpretation | Interpretation in context Are study conclusions presented in the context of prior research? | Not applicable, overall study quality | Face validity results: Eliminated Cognitive testing/ experienced reviewer: Not evaluated | Content validity: Not evaluated | Interrater reliability: Not evaluated | Deleted: relevance to systematic reviews Based on expert review, this question was determined to not be relevant for the purposes of conducting a systematic review.
Presentation and reporting | Completeness, clarity and structure Is the source of funding identified? | Reporting question related to reporting bias | Face validity results: Retained Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = 0.14 Cross-sectional: CVR = Not evaluated Case-control: CVR = 0.14 Case series: CVR = 0.14 | Interrater reliability results: 90% (83%–100%) 0.76 (0.69–0.83) | Retained. Agreement between raters during interrater reliability was high for this question and so question was retained without any changes.
Presentation and reporting | Completeness, clarity and structure Was the funding for this study derived from a source that does not have a vested interest in its results? | Reporting question related to reporting bias | Face validity results: NR Cognitive testing/experienced reviewer results: Retained | Cohort: CVR = -0.14 Cross-sectional: CVR = -0.14 Case-control: CVR = -0.14 Case series: CVR = -0.14 | Interrater reliability: Not evaluated | Deleted: interpretability Added following initial question development but later eliminated. Content validity rating and further discussion with experts recommended that this question be deleted because of the difficulty in identifying on a case-by-case basis organizations that may have a vested interest.

CVR=Content Validity Ratio; NA=not applicable

### Cognitive Testing and Experienced Reviewer Review

On a question-by-question basis, potential users provided feedback on the readability of a 44-item version of the bank including questions, response categories, and instructions. Based on their feedback, we identified particular aspects of individual items that needed revising for greater clarity and direction for the PI and for abstractors separately. Also, because of the substantive expertise of potential users we interviewed, we received comments considering aspects of the item bank design, such as whether particular response categories would provide the distinctions that we were intending and whether additional instructions would be helpful. Reviewers focused on differences between categories such as “no,” “don't know,” and “not applicable.” Following this review, we eliminated two questions: one because of lack of relevance to systematic reviews and a second because it was subsumed into another question (Figure 1 and Table 3).

### Content Validity Testing

An important goal of content validity testing was to identify a core set of questions that experts considered essential in conducting a comprehensive assessment of risk of bias or precision. In the end, a majority of experts considered 24 of a 42-item version of the bank (CRV >0) to be essential across all relevant study designs, 10 items to be either useful or essential across all study designs, and another 6 items to be useful or essential for at least one study design. We eliminated the two questions that the majority of experts considered to be neither essential or nor useful to evaluating risk of bias and precision for any study design type: (1) Is the analysis conducted on an intention-to-treat (ITT) basis? (2) Was the funding for this study derived from a source that does not have a vested interest in its results? The first question was subsumed within another and the second was eliminated from the item bank and not evaluated for interrater reliability (Figure 1 and Table 3).

The source of study funding has been demonstrated to influence the likelihood of publication bias and is therefore an important consideration for evaluating the risk of bias and precision for a body of evidence. Nonetheless, the item was deleted from the evaluation of individual study quality because responses are difficult to interpret in terms of bias. The existence of a source of funding for the study that may have an interest in specific results does not guarantee biased results, nor does the absence of such funding guarantee lack of bias in results.

Although the content validity rating did not easily point to items for exclusion, the results of the content validity rating, in conjunction with interrater reliability scores, helped us determine the need for modifications or deletions.

## Interrater Reliability

Interrater reliability testing was conducted on an item bank of 40 questions. Table 2 presents descriptive information on the 10 studies included in the testing, by methodological approach (9 cohort and 1 case-control study), whether the study included a comparator group (6 studies) and type of study (i.e., treatment, harms, and disease outcomes). We also present the average and range of time it took raters to evaluate the risk of bias and precision of a study using the item bank. Overall, it took raters 48 minutes per study, ranging from 17 to 90 minutes.

Table 3 presents details of results by question including the disposition of each question. Overall, the mean AC1 score per question was relatively low, 0.38 and ranged from 0.10 to 0.88. The mean percent agreement across all items was 66 percent. We found that percent agreement varied by domain, from a high of 90 percent for questions concerning presentation and reporting and 88 percent for those concerning soundness of information to a low of 56 percent for questions concerning followup and 59 percent for those concerning interventions and exposures (results not shown). We further tested if agreement varied significantly between questions that concerned identifying whether specific information was reported in an article and the remaining questions that required more complex judgment on the part of the reviewer. We found that overall, raters agreed 70 percent of the time on their responses to reporting questions and 64 percent on questions requiring judgment (P = 0.09).

Poor results from interrater reliability testing resulted in no clear patterns or conclusions. As a result, we did not eliminate any questions based on this stage of testing. Instead, we used the interrater reliability results to identify and revise questions that performed poorly and to add instruction to PIs to help abstractors interpret questions more clearly.

## Post-Test Revisions

Based on face validity, cognitive testing, content validity, and interrater reliability testing and study team evaluation, we either deleted questions that were considered unnecessary or revised questions (including question syntax, response categories, and instructions). The original 60-item instrument was reduced to 44 items following face validity testing, 42 items following cognitive testing, and 40 items following content validity testing which were used for interrater reliability testing. Following all testing, the final review of items resulted in a bank of 29 items.

Reasons for deletion of questions include lack of relevance to systematic reviews (one question), lack of relevance to evaluation of bias or precision (one question), and overlap with other questions (one question). When possible we collapsed issues of reporting on a specific source of bias or precision within the response categories for direct evaluation of that source of bias or precision (eight questions). For instance, we deleted a reporting question relating to selection bias (“did the authors report differences in baseline characteristics?”) but added a response category within the questions—“did the authors control for differences in baseline characteristics?”—to account for those who reported no differences. (Figure 1 and Table 3 present the disposition of all questions.).

The final version of the RTI Item Bank is presented in Appendix B. The bank contains 29 questions, multiple-choice response categories and extensive instructions for PIs and abstractors to assist them in developing criteria for considering the issue being investigated by the question. The order of the questions in the item bank is according to the study domain structure presented by Deeks and colleagues and is generally intended to allow the reviewer to consider the various risks of bias and precision issues of a study according to the presentation order of a manuscript. Table 4 maps each question to the risk of bias or precision and methods description and also lists relevant study designs.

Because of the integral nature of reporting to evaluating risk of bias and precision, the item bank evaluates some elements of risk of bias and precision through a cluster of questions. For instance, questions about selection bias in the creation of the sample require questions about whether inclusion/exclusion criteria were reported and measured appropriately before the reviewer can judge whether or not they were applied equally to all arms of the study (Questions 2, 3, and 4). The PI's role in systematic review is to determine the appropriate mix of questions necessary for evaluation the dominant risks of bias and threats to precision in the studies being reviewed.