# References

1 Lohr KN. Emerging methods in comparative effectiveness and safety: symposium overview and summary. Med Care. Oct. 2007;45(10 Supl 2):S5-S8. [pmid: 17909383].
2 Viswanathan M. Systematic Review: Assessing the Quality of Individual Studies. Rockville, MD. Agency for Healthcare Quality and Review. 2010. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/slides/?pageAction=displaySlides&t k=24.
3 Norris SL, Atkins D. Challenges in using nonrandomized studies in systematic reviews of treatment interventions. Ann Intern Med. Jun. 21. 2005;142(12 Pt 2):1112-19. [pmid: 15968036].
4 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
5 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0. Rockville, MD. Agency for Healthcare Research and Quality. 2007. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
6 Juni P, Altman DG, Egger M. Systematic reviews in health care: assessing the quality of controlled clinical trials. Br Med J. 2001;323:42-46. [pmid: 11440947].
7 Higgins JPT, Green S. Cochrane handbook for systematic reviews of interventions version 5.0.2. London. The Cochrane Collaboration. 2009. Available at: www.cochrane-handbook.org.
8 Rothman KJ, Greenland S, Lash TL. Modern Epidemiology. 3rd ed. Philadelphia, PA. Lippincott, Williams, & Wilkins. 2008.
9 West SL, King V, Carey TS, et al. Systems to rate the strength of scientific evidence, Evidence Report/Technology Assessment No. 47. Rockville, MD. Agency for Healthcare Research and Quality. 2002. AHRQ Publication No. -02-E016.
10 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
11 Sanderson S, Tatt ID, Higgins JP. Tools for assessing quality and susceptibility to bias in observational studies in epidemiology: a systematic review and annotated bibliography. Int J Epidemiol. Jun. 2007;36(3):666-76. [pmid: 17470488].
12 Katrak P, Bialocerkowski AE, Massy-Westropp N, et al. A systematic review of the content of critical appraisal tools. BMC Med Res Methodol. 2004;4:22. [pmid: 15369598].
13 Thomas H. Quality assessment tool for quantitative studies, Effective Public Health Practice Project. Toronto. McMaster University.
14 Wells G, Shay B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Ottawa. University of Ottawa. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/slides/?pageAction=displaySlides&t k=24.
15 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Commun Health. 1998;52:377-84.
16 Zaza S, Wright-De Aguero LK, Briss PA, et al. Data collection instrument and procedure for systematic reviews in the Guide to Community Preventive Services. Task Force on Community Preventive Services. Am J Prev Med. Jan. 2000;18(1 Suppl):44-74. [pmid: 10806979].
17 Cowley DE. Prostheses for primary total hip replacement. A critical appraisal of the literature. Int J Technol Assess Health Care. Fall. 1995;11(4):770-8. [pmid: 8567209].
18 Reisch JS, Tyson JE, Mize SG. Aid to the evaluation of therapeutic studies. Pediatrics. Nov. 1989;84(5):815-27. [pmid: 2797977].
19 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr. 19. 2000;283(15):2008-12. [pmid: 10789670].
20 Peipert JF, Phipps MG. Observational studies. Clin Obstet Gynecol. Jun. 1998;41(2):235-244. [pmid: 9646956].
21 Wilt TJ, Lederle FA, MacDonald R, et al. Comparison of Endovascular and Open Surgical Repairs for Abdominal Aortic Aneurysm, Structured Abstract, Evidence Report/Technology Assessment No. 144. (Prepared by the University of Minnesota Evidence-based Practice Center under Contract No. 290-02-0009). Rockville, MD. Agency for Healthcare Research and Quality. August. 2006. AHRQ Publication No. 06-E017.
22 Lau J, Ioannidis JPA, Balk E, et al. Evaluation of Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments, Evidence Report/Technology Assessment Number 26. (Prepared by The New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. May. 2001. AHRQ Publication No. 01-E006.
23 Sharma M, Clark H, Armour T, et al. Acute Stroke: Evaluation and Treatment, Evidence Report/Technology Assessment No. 127. (Prepared by the University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. July. 2005. AHRQ Publication No. 05-E023-2.
24 Jadad AR, Boyle M, Cunningham C, et al. Treatment of Attention-Deficit/Hyperactivity Disorder, Evidence Report/Technology Assessment No. 11. (Prepared by McMaster University under Contract No. 290-97-0017). Rockville, MD. Agency for Healthcare Research and Quality. November. 1999. AHRQ Publication No. 00-E005.
25 Myers ER, Bastian LA, Havrilesky LJ, et al. Management of Adnexal Mass, Evidence Report/Technology Assessment No. 130. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. February. 2006. AHRQ Publication No. 06-E004.
26 Lau J, Balk E, Rothberg M, et al. Management of Clinically Inapparent Adrenal Mass, Evidence Report/Technology Assessment No. 56. (Prepared by New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. May. 2002. AHRQ Publication No. 02-E014.
27 Chou R, Fu R, Carson S, et al. Empirical Evaluation of the Association Between Methodological Shortcomings and Estimates of Adverse Events, Technical Review No. 13. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024). Rockville, MD. Agency for Healthcare Research and Quality. October. 2006. AHRQ Publication No. 07-0003.
28 Hardy M, Coulter I, Venuturupalli S, et al. Ayurvedic Interventions for Diabetes Mellitus: A Systematic Review, Evidence Report/Technology Assessment No. 41. (Prepared by Southern California Evidence-based Practice Center/RAND under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Review and Quality. 2001. AHRQ Publication No. 01-E040.
29 Balk E, Chung M, Raman G, et al. B Vitamins and Berries and Age-Related Neurodegenerative Disorders, Evidence Report/Technology Assessment No. 134. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. April. 2006. AHRQ Publication No. 06-E008.
30 Catlett C, Perl T, Jenckes MW, et al. Training of Clinicians for Public Health Events Relevant to Bioterrorism Preparedness, Evidence Report/Technology Assessment No. 51. (Prepared by Johns Hopkins Evidence-based Practice Center under Contract No. 290-97-006). Rockville, MD. Agency for Healthcare Research and Quality. January. 2002. AHRQ Pub. No. 02-E011.
31 Bravata DM, McDonald K, Owens DK, et al. Bioterrorism Preparedness and Response: Use of Information Technologies and Decision Support Systems, Evidence Report/Technology Assessment No. 59. (Prepared by University of California San Francisco B Stanford Evidence-based Practice Center under Contract No290-97-0013). Rockville, MD. Agency for Healthcare Research and Quality. June. 2002. AHRQ Publication No. 02-E028.
32 Appel LJ, Robinson KA, Guallar E, et al. Utility of Blood Pressure Monitoring Outside of the Clinic Setting, Evidence Report/Technology Assessment No. 63. (Prepared by the Johns Hopkins Evidence-based Practice Center under Contract No 290-97-006). Rockville, MD. Agency for Healthcare Research and Quality. November. 2002. AHRQ Publication No. 03-E004.
33 Balion C, Santaguida P, Hill S, et al. Testing for BNP and NT-proBNP in the Diagnosis and Prognosis of Heart Failure, Evidence Report/Technology Assessment No. 142. (Prepared by the McMaster University Evidence-based Practice Center under Contract No. 290-02-0020). Rockville, MD. Agency for Healthcare Research and Quality. September. 2006. AHRQ Publication No. 06-E014.
34 Viswanathan M, King VJ, Bordley C, et al. Management of Bronchiolitis in Infants and Children, Evidence Report/Technology Assessment No. 69. (Prepared by RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center under Contract No. 290-97-0011). Rockville, MD. U.S. Department of Health and Human Services, Agency for Healthcare Research and Quality. January. 2003. AHRQ Publication No. 03-E014.
35 Ford JG, Howerton MW, Bolen S, et al. Knowledge and Access to Information on Recruitment of Underrepresented Populations to Cancer Clinical Trials, Evidence Report/Technology Assessment No. 122. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-02-0018). Rockville, MD. Agency for Healthcare Research and Quality. June. 2005. AHRQ Publication No. 05-E019-2.
36 Ellis P, Robinson P, Ciliska D, et al. Diffusion and Dissemination of Evidence-based Cancer Control Interventions, Evidence Report/Technology Assessment Number 79. (Prepared by McMaster University under Contract No. 290-97-0017). Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. AHRQ Publication No. 03-E033.
37 Whelan TJ, O'Brien MA, Villasis-Keever M, et al. Impact of Cancer-Related Decision Aids, Evidence Report/Technology Assessment Number 46. (Prepared by McMaster University under Contract No. 290-97-0017). Rockville, MD. Agency for Healthcare Research and Quality. July. 2002. AHRQ Publication No. 02-E004.
38 Ammerman A, Lindquist C, Hersey J, et al. Efficacy of interventions to modify dietary behavior related to cancer risk, Evidence Report/Technology Assessment No. 25. (Contract No. 290-97-0011 to the Research Triangle Institute-University of North Carolina at Chapel Hill Evidence-based Practice Center). AHRQ Rockville, MD. Agency for Healthcare Research and Quality. February. 2001. Publication No. 01-E029.
39 McAlister F, Ezekowitz J, Wiebe N, et al. Cardiac Resynchronization Therapy for Congestive Heart Failure, Evidence Report/Technology Assessment No. 106 (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023). Rockville MD. Agency for Healthcare Research and Quality. November. 2004. AHRQ Publication No. 05-E001-2.
40 Oliver D, Schein OD, David S, Friedman DS, Lee A, Fleisher LA, et al. Anesthesia Management During Cataract Surgery, Evidence Report/Technology Assessment No. 16. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-097-0006). Rockville, MD. Agency for Healthcare Research and Quality. December. 2001. AHRQ Publication No. 01-E017.
41 Jampel H, Lubomski L, Friedman D. Treatment of Coexisting Cataract and Glaucoma, Evidence Report/Technology Assessment Number 38. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-97-0006). Rockville, MD. Agency for Healthcare Research and Quality. June. 2003. AHRQ Publication No. 03-E041.
42 Viswanathan M, Ammerman A, Eng E, et al. Community-Based Participatory Research: Assessing the Evidence, Evidence Report/Technology Assessment No. 99. (Prepared by RTI University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. July. 2004. AHRQ Publication 04-E022-2.
43 Rostom A, Dubé C, Cranney A, et al. Celiac Disease, Evidence Report/Technology Assessment No. 104. (Prepared by the University of Ottawa Evidence-based Practice Center, under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. September. 2004. AHRQ Publication No. 04-E029-2.
44 Grady D, Chaput L, Kristof M. Results of Systematic Review of Research on Diagnosis and Treatment of Coronary Heart Disease in Women, Evidence Report/Technology Assessment No. 80. (Prepared by the University of California, San Francisco-Stanford Evidence-based Practice Center under Contract No 290-97-0013). Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. AHRQ Publication No. 03-0035.
45 Marinopoulos SS, Dorman T, Ratanawongsa N, et al. Effectiveness of Continuing Medical Education, Evidence Report/Technology Assessment No. 149. (Prepared by the Johns Hopkins Evidence-based Practice Center, under Contract No. 290-02-0018). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. AHRQ Publication No. 07-E006.
46 McCrory DC, Brown C, Gray RN, et al. Management of Acute Exacerbations of COPD, Evidence Report/Technology Assessment No. 19. (Contract 290-97-0014 to the Duke University Evidence-based Practice Center). Rockville, MD. Agency for Healthcare Research and Quality. March. 2001. AHRQ Publication No. 01-E003.
47 Flamm CR, Aronson N, Bohn R, et al. Use of Epoetin for Anemia in Chronic Renal Failure, Evidence Report/Technology Assessment No. 29. (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center under Contract No. 290-97-0015). Rockville, MD. Agency for Healthcare Research and Quality. August. 2001. AHRQ Publication No. 01-E016.
48 Viswanathan M, Visco AG, Hartmann K, et al. Cesarean Delivery on Maternal Request, Evidence Report/Technology Assessment No. 133. (Prepared by the RTI International-University of North Carolina Evidence-Based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. March. 2006. AHRQ Publication No. 06-E009.
49 Bonito AJ, Palton LL, Shugars DA, et al. Management of Dental Patients Who are HIV-positive, Evidence Report/Technology Assessment No. 37. (Contract 290-97-0011 to the Research Triangle Institute-University of North Carolina at Chapel Hill Evidence-based Practice Center). Rockville, MD. Agency for Healthcare Research and Quality. March. 2002. AHRQ Publication No. 01-E042.
50 Bader JD, Bonito AJ, Shugars DA. Cardiovascular Effects of Epinephrine on Hypertensive Dental Patients, Evidence Report/Technology Assessment Number 48. (Prepared by Research Triangle Institute under Contract No. 290-97-0011). Rockville, MD. Agency for Healthcare Research and Quality. July. 2002. AHRQ Publication No. 02-E006.
51 Golden S, Boulware LE, Berkenblit G, et al. Use of Glycated Hemoglobin and Microalbuminuria in the Monitoring of Diabetes Mellitus, Evidence Report/Technology Assessment No. 84. (Prepared by Johns Hopkins Evidence-based Practice Center under Contract No. 290-97-0006). Rockville, MD. Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services. October. 2003. AHRQ Publication No. 04-E001.
52 Ross SD, Levine C, Ganz N, et al. Systematic Review of the Current Literature Related to Disability and Chronic Fatigue Syndrome, Evidence Report/Technology Assessment No. 66. (Prepared by MetaWorks Inc Evidence-based Practice Center under Contract No 290-97-0016). Rockville, MD. Agency for Healthcare Research and Quality. December. 2002. AHRQ Publication No. 03-E007.
53 Segal JB, Eng J, Jenckes MW, et al. Diagnosis and Treatment of Deep Venous Thrombosis and Pulmonary, Embolism Evidence Report/Technology Assessment Number 68. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-97-0007). Rockville, MD. Agency for Healthcare Research and Quality. March. 2003. AHRQ Publication No. 03-E016.
54 Berkman ND, Bulik CM, Brownley KA, et al. Management of Eating Disorders, Evidence Report/Technology Assessment No. 135. (Prepared by the RTI International-University of North Carolina Evidence-Based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. April. 2006. AHRQ Publication No. 06-E010.
55 Lorenz K, Lynn J, Morton SC, et al. End-of-Life Care and Outcomes, Evidence Report/Technology Assessment No. 110. (Prepared by the Southern California Evidence-based Practice Center, under Contract No. 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. December. 2004. AHRQ Publication No. 05-E004-2.
56 Aronson N, Flamm CR, Mark D, et al. Endoscopic Retrograde Cholangiopancreatography, Evidence Report/Technology Assessment Number 50. (Prepared by Blue Cross and Blue Shield Association under Contract No. 290-97-001-5). Rockville, MD. Agency for Healthcare Research and Quality. June. 2002. AHRQ Publication No. 02-E017.
57 Ross SD, Estok R, Chopra S, et al. Management of Newly Diagnosed Patients with Epilepsy: A Systematic Review of the Literature, Evidence Report/Technology Assessment No. 39. (Contract 290-97-0016 to MetaWorks, Inc.). Rockville, MD. Agency for Healthcare Research and Quality. September. 2001. AHRQ Publication No. 01-E038.
58 Chapell R, Reston J, Snyder D. Management of Treatment-Resistant Epilepsy, Evidence Report/Technology Assessment No. 77. (Prepared by the ECRI Evidence-based Practice Center under Contract No 290-97-0020). Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. AHRQ Publication No. 03-0028.
59 Viswanathan M, Hartmann K, Palmieri R, et al. The Use of Episiotomy in Obstetrical Care: A Systematic Review, Evidence Report/ Technology Assessment No. 112. (Prepared by the RTI-UNC Evidence-based Practice Center, under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. May. 2005. AHRQ Publication No. 05-E009-2.
60 Perrin EC, Cole CH, Frank DA, et al. Criteria for Determining Disability in Infants and Children: Failure to Thrive, Evidence Report/Technology Assessment No. 72. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. March. 2003. AHRQ Publication No. 03-E026.
61 McDonagh MS, Carson S, Ash JS, et al. Hyperbaric Oxygen Therapy for Brain Injury, Cerebral Palsy, and Stroke, Evidence Report/Technology Assessment No. 85. (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No 290-97-0018). Rockville, MD. Agency for Healthcare Research and Quality. September. 2003. AHRQ Publication No. 04-E003.
62 Berkman ND, DeWalt DA, Pignone MP, et al. Literacy and health outcomes, Evidence Report/Technology Assessment No. 87. (Prepared by RTI International-University of North Carolina under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. 2004. AHRQ Publication No. 04-E007-2.
63 Oremus M, Hanson M, Whitlock R, et al. The Uses of Heparin To Treat Burn Injury, Evidence Report/Technology Assessment No. 148. (Prepared by the McMaster University Evidence-based Practice Center, under Contract No. 290-02-0020). Rockville, MD. Agency for Healthcare Research and Quality. December. 2006. AHRQ Publication No. 07-E004.
64 Gebo KA, Jenckes MJ, Chander G, et al. Management of Chronic Hepatitis C, Evidence Report/Technology Assessment No. 60. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No 290-97-0006). Rockville, MD. Agency for Healthcare Research and Quality. July. 2002. AHRQ Publication No. 02-E030.
65 Santaguida PL, Balion C, Hunt D, et al. Diagnosis, Prognosis, and Treatment of Impaired Glucose Tolerance and Impaired Fasting Glucose, Evidence Report/Technology Assessment No. 128. (Prepared by the McMaster University Evidence-based Practice Center under Contract No. 290-02-0020). Rockville, MD. Agency for Healthcare Research and Quality. September. 2005. AHRQ Pub. No 05-E026-2.
66 Buscemi N, Vandermeer B, Friesen C, et al. Manifestations and Management of Chronic Insomnia in Adults, Evidence Report/Technology Assessment No. 125. (Prepared by the University of Alberta Evidence-based Practice Center, under Contract No. C400000021). Rockville, MD. Agency for Healthcare Research and Quality. June. 2005. AHRQ Publication No. 05-E021-2.
67 Cole C, Binney G, Casey P, et al. Criteria for Determining Disability in Infants and Children: Low Birth Weight, Evidence Report/Technology Assessment No. 70. (Prepared by Tufts New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. December. 2002. AHRQ Publication No. 03-E010.
68 Meenan RT, Saha S, Chou R, et al. Effectiveness and Cost-Effectiveness of Echocardiography and Carotid Imaging in the Management of Stroke, Evidence Report/Technology Assessment Number 49. (Prepared by Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-97-0018). Rockville, MD. Agency for Healthcare Research and Quality. July. 2002. AHRQ Publication No. 02-EO22.
69 Cook D, Meade M, Guyatt G, et al. Criteria for Weaning From Mechanical Ventilation, Evidence Report/Technology Assessment No. 23. (Prepared by McMaster University under Contract No. 290-97-0017). Rockville MD. Agency for Healthcare Research and Quality. November. 2000. AHRQ Publication No. 01-E010.
70 Buscemi N, Vandermeer B, Pandya R, et al. Melatonin for Treatment of Sleep Disorders, Evidence Report/Technology Assessment No. 108. (Prepared by the University of Alberta Evidence-based Practice Center, under Contract No. 290-02-0023). Rockville, MD. Agency for Healthcare Research and Quality. November. 2004. AHRQ Publication No. 05-E002-2.
71 Nelson HD, Haney E, Humphrey L, et al. Management of Menopause-Related Symptoms, Evidence Report/Technology Assessment No. 120. (Prepared by the Oregon Evidence-based Practice Center, under Contract No. 290-02-0024). Rockville, MD. Agency for Healthcare Research and Quality. March. 2005. AHRQ Publication No. 05-E016-2.
72 Beach MC, Cooper LA, Robinson KA, et al. Strategies for Improving Minority Healthcare Quality, Evidence Report/Technology Assessment No. 90. (Prepared by the Johns Hopkins University Evidence-based Practice Center, Baltimore, MD). Rockville, MD. Agency for Healthcare Research and Quality. January. 2004. AHRQ Publication No. 04-E008-02.
73 McCrory DC, Pompeii LA, Skeen MB, et al. Criteria to Determine Disability Related to Multiple Sclerosis, Evidence Report/Technology Assessment No. 100. (Prepared by the Duke Evidence-based Practice Center, Durham, NC, under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. May. 2004. AHRQ Publication No. 04-E019-2.
74 Ip S, Glicken S, Kulig J, et al. Management of Neonatal Hyperbilirubinemia, Evidence Report/Technology Assessment No. 65. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. U.S. Department of Health and Human Services, Agency for Healthcare Research and Quality. January. 2003. AHRQ Publication No. 03-E011.
75 Shekelle PG, Morton SC, Maglione MA, et al. Pharmacological and Surgical Treatment of Obesity, Evidence Report/Technology Assessment No. 103. (Prepared by the Southern California-RAND Evidence-Based Practice Center, Santa Monica, CA, under contract Number 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. July. 2004. AHRQ Publication No. 04-E028-2.
76 Hodge W, Barnes D, Schachter H, et al. Effects of Omega-3 Fatty Acids on Eye Health, Evidence Report/Technology Assessment No. 117. (Prepared by University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. July. 2005. AHRQ Publication No. 05-E008-2.
77 MacLean CH, Issa AM, Newberry SJ, et al. Effects of Omega-3 Fatty Acids on Cognitive Function with Aging, Dementia, and Neurological Diseases, Evidence Report/Technology Assessment No. 114. (Prepared by the Southern California Evidence-based Practice Center, under Contract No. 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. February. 2005. AHRQ Publication No. 05-E011-2.
78 MacLean CH, Mojica WA, Morton SC, et al. Effects of Omega-3 Fatty Acids on Lipids and Glycemic Control in Type II Diabetes and the Metabolic Syndrome and on Inflammatory Bowel Disease, Rheumatoid Arthritis, Renal Disease, Systemic Lupus Erythematosus, and Osteoporosis, Evidence Report/Technology Assessment No. 89. (Prepared by Southern California/RAND Evidence-based Practice Center, under Contract No. 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. March. 2004. AHRQ Publication No. 04-E012-2.
79 Lewin GA, Schachter HM, Yuen D, et al. Effects of Omega-3 Fatty Acids on Child and Maternal Health, Evidence Report/Technology Assessment No. 118. (Prepared by the University of Ottawa Evidence-based Practice Center, under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. August. 2005. AHRQ Publication No. 05-E025-2.
80 Schachter HM, Kourad K, Merali Z, et al. Effects of Omega-3 Fatty Acids on Mental Health, Evidence Report/Technology Assessment No. 116. (Prepared by the University of Ottawa Evidence-based Practice Center, Under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. July. 2005. AHRQ Publication No. 05-E022-2.
81 Bonis PA, Chung M, Tatsioni A, et al. Effects of Omega-3 Fatty Acids on Organ Transplantation, Evidence Report/Technology Assessment No. 115. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. February. 2005. AHRQ Publication No. 05-E012-2.
82 Schachter H, Reisman J, Tran K, et al. Health Effects of Omega-3 Fatty Acids on Asthma, Evidence Report/Technology Assessment No. 91. (Prepared by University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. March. 2004. AHRQ Publication No. 04-E013-2.
83 Wang C, Chung M, Lichtenstein A, et al. Effects of Omega-3 Fatty Acids on Cardiovascular Disease, Evidence Report/Technology Assessment No. 94. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. March. 2004. AHRQ Publication No. 04-E009-2.
84 Marcy M, Takata G, Chan LS, et al. Management of Acute Otitis Media, Evidence Report/Technology Assessment No. 15. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. May. 2001. AHRQ Publication No. 01-E010.
85 Shekelle P, Takata G, Chan LS, et al. Diagnosis, Natural History, and Late Effects of Otitis Media with Effusion, Evidence Report/Technology Assessment No. 55. (Prepared by Southern California Evidence-based Practice Center under Contract No 290-97-0001, Task Order No. 4). Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. AHRQ Publication No. 03-E023.
86 Hickam DH, Severance S, Feldstein A, et al. The Effect of Health Care Working Conditions on Patient Safety, Evidence Report/Technology Assessment Number 74. (Prepared by Oregon Health & Science University under Contract No. 290-97-0018). Rockville, MD. Agency for Healthcare Research and Quality. April. 2003. AHRQ Publication No. 03-E024.
87 Gaynes BN, Gavin N, Meltzer-Brody S, et al. Perinatal Depression: Prevalence, Screening Accuracy, and Screening Outcomes, Evidence Report/Technology Assessment No. 119. (Prepared by the RTI-University of North Carolina Evidence-based Practice Center, under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. February. 2005. AHRQ Publication No. 05-E006-2.
88 Holtzman J, Schmitz K, Babes G, et al. Effectiveness of Behavioral Interventions to Modify Physical Activity Behaviors in General Populations and Cancer Patients and Survivors, Evidence Report/Technology Assessment No. 102. (Prepared by the Minnesota Evidence-based Practice Center, under Contract No. 290-02-0009). Rockville, MD. Agency for Healthcare Research and Quality. June. 2004. AHRQ Publication No. 04-E027-2.
89 Myers ER, Blumrick R, Christian AL, et al. Management of prolonged pregnancy, Evidence Report/Technology Assessment No. 53. (Prepared by Duke Evidence-based Practice Center, Durham, NC, under Contract No. 290-97-0014). Rockville, MD. Agency for Healthcare Research and Quality. May. 2002. AHRQ Publication No. 02-E018.
90 Bush DE, Ziegelstein RC, Patel UV, et al. Post-Myocardial Infarction Depression, Evidence Report/Technology Assessment No. 123. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-02-0018). Rockville, MD. Agency for Healthcare Research and Quality. May. 2005. AHRQ Publication No. 05-E018-2.
91 Long A, McFadden C, DeVine D, et al. Management of Allergic and Nonallergic Rhinitis, Evidence Report/Technology Assessment No. 54. (Prepared by New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). Rockville, MD. Agency for Healthcare Research and Quality. May. 2002. AHRQ Pub. No. 02-E024.
92 Balk E, Chung M, Chew P, et al. Effects of Soy on Health Outcomes, Evidence Report/Technology Assessment No. 126. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. August. 2005. AHRQ Publication No. 05-E024-2.
93 McCrory DC, Samsa GP, Hamilton BB, et al. Treatment of Pulmonary Disease Following Cervical Spinal Cord Injury, Evidence Report/Technology Assessment Number 27. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-97-0014). Rockville, MD. Agency for Healthcare Research and Quality. September. 2001. AHRQ Publication No. 01-E014.
94 DeForge D, Blackmer J, Moher D, et al. Sexuality and Reproductive Health Following Spinal Cord Injury, Evidence Report/Technology Assessment No. 109. (Prepared by the University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville, MD. Agency for Healthcare Research and Quality. November. 2004. AHRQ Publication No. 05-E003-2.
95 Ranney L, Melvin C, Lux LJ, et al. Tobacco use: prevention, cessation, and control, Evidence Report/Technology Assessment No. 140. (Prepared by the RTI-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. 2006. AHRQ Pub. No. 06-E015.
96 Kiddoo D, Klassen TP, Lang ME, et al. The Effectiveness of Different Methods of Toilet Training for Bowel and Bladder Control, Evidence Report/Technology Assessment No. 147. (Prepared by the University of Alberta Evidence-based Practice Center, under contract number 290-02-0023). Rockville, MD. Agency for Healthcare Research and Quality. December. 2006. AHRQ Publication No. 07-E003.
97 Kane RL, Saleh KJ, Wilt TJ, et al. Total Knee Replacement, Evidence Report/Technology Assessment No. 86. (Prepared by the Minnesota Evidence-based Practice Center, Minneapolis, MN). Rockville, MD. Agency for Healthcare Research and Quality. December. 2003. AHRQ Publication No. 04-E006-2.
98 Viswanathan M, Hartmann K, McKoy N, et al. Management of Uterine Fibroids: An Update of the Evidence, Evidence Report/Technology Assessment No. 154. (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. July. 2007. AHRQ Publication No. 07-E011.
99 Guise JM, McDonagh MS, Hashima J, et al. Vaginal Birth After Cesarean (VBAC), Evidence Report/Technology Assessment No. 71. (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-97-0018). Rockville, MD. Agency for Healthcare Research and Quality. March. 2003. AHRQ Publication No. 03-E018.
100 Velmahos GC, Kern J, Chan L, et al. Prevention of Venous Thromboembolism After Injury, Evidence Report/ Technology Assessment No. 22. (Prepared by Southern California Evidence-based Practice Center/RAND under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. November. 2000. AHRQ Publication No. 01-E004.
101 Chan LS, Kipke MD, Schneir A, et al. Preventing Violence and Related Health-Risking Social Behaviors In Adolescents, Evidence Report/Technology Assessment No. 107. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-2003). Rockville, MD. Agency for Healthcare Research and Quality. October. 2004. AHRQ Publication No. 04-E032-2.
102 Beach J, Rowe BH, Blitz S, et al. Diagnosis and Management of Work-Related Asthma, Evidence Report/Technology Assessment No. 129. (Prepared by the University of Alberta Evidence-based Practice Center, under Contract No. 290-02-0023). Rockville, MD. Agency for Healthcare Research and Quality. November. 2005. AHRQ Publication No. 06-E003-2.
103 Coulter ID, Hardy ML, Favreau JT, et al. Mind-Body Interventions for Gastrointestinal Conditions, Evidence Report/Technology Assessment No. 40. (Prepared by Southern California Evidence-based Practice Center/RAND under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. July. 2001. AHRQ Publication No. 01-E030.
104 Hersh WR, Hickam DH, Severance SM, et al. Telemedicine for the Medicare Population: Update, Evidence Report/Technology Assessment No. 131. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024). Rockville, MD. Agency for Healthcare Research and Quality. February. 2006. AHRQ Publication No. 06-E007.
105 Levine C, Armstrong K, Chopra S, et al. Diagnosis and management of specific breast abnormalities, Evidence Report/Technology Assessment No. 33. (Prepared by MetaWorks, Inc, Boston, MA under Contract No. 290-97-0016). Rockville, MD. Agency for Healthcare Research and Quality. September. 2001. AHRQ Publication No. 01-E046.
106 Matchar DB, Thakur ME, Grossman I, et al. Testing for Cytochrome P450 Polymorphisms in Adults With Non-Psychotic Depression Treated With Selective Serotonin Reuptake Inhibitors (SSRIs), Evidence Report/Technology Assessment No. 146. (Prepared by the Duke Evidence-based Practice Centerunder Contract No. 290-02-0025.). Rockville, MD. Agency forHealthcare Research and Quality. November. 2006. AHRQ Publication No. 07-E002.
107 Seidenfeld J, Samson DJ, Bonnell CJ, et al. Management of Small Cell Lung Cancer, Evidence Report/Technology Assessment No. 143. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-02-0026). Rockville, MD. Agency for Healthcare Research and Quality. July. 2006. AHRQ Publication No. 06-E016.
108 Myers ER, Havrilesky LJ, Kulasingam SL, et al. Genomic Tests for Ovarian Cancer Detection and Management, Evidence Report/Technology Assessment No. 145. (Prepared by the Duke University Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. October. 2006. AHRQ Publication No. 07-E001.
109 ECRI Institute Evidence-based Practice Center. Quality item checklist for SINGLE-GROUP studies. 2008.
110 University Of Alberta Evidence-Based Practice Centre. Quality Assessment Tool for Observational Analytical Studies.
111 National Institute for Health and Clinical Excellence. The guidelines manual. London. National Institute for Health and Clinical Excellence. 2007. Available at: www.nice.org.uk.
112 Khan KS, ter Riet G, Glanville J, et al., editors. Undertaking Systematic Reviews of Research on Effectiveness. 2nd ed. York, U.K. NHS Centre for Reviews and Dissemination. 2001.
113 Johnston P, Wilkinson K. Enhancing validity of critical tasks selected for college and university program portfolios. National Forum of Teacher Education Journal. 2009;19(3):1-6.
114 Crisp AH, Callender JS, Halek C, et al. Long-term motrality in anorexia nervosa: A 20-year follow-up of the St. George's and Aberdeen cohorts. Br J Psychiatry. 1992;161:104-7. [pmid: 1638303].
115 Daniel M, Green LW, Marion SA, et al. Effectiveness of community-directed diabetes prevention and control in a rural Aboriginal population in British Columbia, Canada. Soc Sci Med. 1999;48:815-832. [pmid: 10190643].
116 Hedderson MM, Weiss NS, Sacks DA, et al. Pregnancy weight gain and risk of neonatal complications. Obstet Gynecol. 2006;108:1153-61. [pmid: 17077237].
117 Di Lieto A, Iannotti F, De Falco M, et al. Immunohistochemical detection of insulinlike growth factor type I receptor and uterine volume changes in gonadotropin-releasing hormone analog-treated uterine leiomyomas. Am J Obstet Gynecol. 2003;188:702-6. [pmid: 12634644].
118 Coleman FH. Safety and efficacy of combined ritodrine and magnesium sulfate for preterm labor: a method for reduction of complications. American Journal of Perinatology. 1990;7(4):366-9. [pmid: 2222631].
119 Schindl M, Birner P, Reingrabner M, et al. Elective cesarean section vs. spontaneous delivery: a comparative study of birth experience. Acta Obstet Gynecol Scand. 2003;82:834-40. [pmid: 12911445].
120 Fouad MN, Kiefe CI, Bartolucci AA, et al. A hypertension control program tailored to unsilled and minority workers. Ethnicity Dis. 1997;7:191-9.
121 Baker DW, Gazmararian JA, Williams MV, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. Am J Public Health. 2002;92(8):1278-83. [pmid: 12144984].
122 Kinney TR, Helms RW, O'Branski EE, et al. Safety of hydroxyurea in children with sickle cell anemia: results of the HUG-KIDS Study, a phase I/II trial. Blood. 1999;94:1550-4. [pmid: 10477679].
123 Van Ham MAPC, van Dongen PWJ, Mulder J. Maternal consequences of caesarean section. A retrospective study of intra-operative and postoperative maternal complications of caesarean section during a 10-year period. European Journal of Obstetrics and Gynecology. 1997;74:1-6.
124 Blood E, Spratt KF. Disagreement on agreement: Two alternative agreement coefficients. Paper 186-2007. SAS Global Forum. 2007:1-12.
125 Feinstein AR, Cicchetti DV. High agreement but low kappa: I. The problems of two paradoxes. J Clin Epidemiol. 1990;43(6):543-9. [pmid: 2348207].