# Methods

The project was conducted in two phases. The preliminary period, phase 1, resulted in the compilation of potential questions for the item bank. Phase 2 included face validity testing, cognitive testing, content validity testing, and interrater reliability testing. Our goal was to create an item bank where users choose a relevant subset of the included questions. Nonetheless, during the development process, feedback from our Technical Expert Panel (TEP) and testers indicated that a large bank of items would be a constraint to usability. Therefore, we sought to reduce the number of items in the bank to questions relevant for evaluating risk of bias and precision in observational studies and eliminated potential questions concerning applicability, those that were limited in relevance to RCTs, were not relevant to systematic reviews, overlapped with other questions, or had responses that were uninterpretable in the context of evaluating bias or precision. When possible, we attempted to focus on direct evaluations of bias and precision, and subsumed evaluations of limitations resulting from deficiencies in quality of reporting into these questions. We also indicated when specific questions may be excluded for individual studies or for the body of evidence being evaluated. These deletions and modifications occurred over each of the stages of validity and reliability testing, and as a result, some items did not proceed to next stage of testing; the results section provides additional details on the disposition of specific questions.

## Compilation of Potential Questions for Item Bank

During phase 1, we compiled a large number of items which had been used previously in AHRQ-sponsored systematic reviews of the evidence and other instruments to evaluate the quality (risk of bias, precision, and other threats to validity) of individual observational studies.21-108 Some instruments were identified and forwarded to the team by TEP members.13,16,109-112 To ensure that items addressed all important domains related to risk of bias and other threats to validity, we sorted items into quality domains identified by Deeks et al.10 We created a prototype item bank containing questions addressing all relevant domains and corresponding multiple choice response categories. The tool included instructions for use and directions for interpreting individual items for principal investigators and abstractors.

### Face Validity Testing

In phase 2, we convened a Technical Expert Panel (TEP) composed of 16 senior staff from across Evidence-based Practice Centers (EPCs) and the Agency for Healthcare Research and Quality (AHRQ). The TEP provided expert input throughout the process of finalizing the item bank including reviewing and advising on the proposed conceptual framework; ensuring that the item bank questions evaluated all the critical domains identified by Deeks et al. listed above; sharing their knowledge of existing instruments that have been used for measuring risk of bias or precision; and evaluating the face validity of an early draft of the item bank containing 60 questions (whether they believed that questions would be interpreted correctly and appeared to measure what they were intended to measure).

## Cognitive Testing and Experienced Reviewer Review

A preliminary version of the item bank containing 44 questions was reviewed by 9 potential users who were staff at 6 AHRQ-funded Evidence-based Practice Centers (RAND/RTI International–University of North Carolina [RTI-UNC], University of Alberta, University of Connecticut, University of Minnesota, and Vanderbilt University). Each reviewer independently participated in cognitive testing of the instrument and responded to questions concerning the readability of particular instructions, questions, and response categories. The cognitive interviewer (at least one of the study principal investigators [PIs] accompanied by a notetaker) quizzed the interviewee to determine whether all portions of the instrument were being read and interpreted in the manner they were intended. In addition, because interviewees were experienced in conducting systematic reviewers, each was asked to also evaluate the instrument in relation to whether it contained sufficient and appropriate questions to obtain information on all critical domains.

## Content Validity Testing

Seven TEP members participated in a content validity testing of a 42-item version of the item bank. Content validity raters reviewed each item bank question and determined whether they considered the question to be essential, useful, or not necessary for evaluating study risk of bias and precision. Raters repeated the exercise four times separately in relation to cohort, case control, case series, and cross-sectional studies. Results are summarized through a Content Validity Ratio (CVR) score that describes the extent to which the group of reviewers considered each item to be essential to the operationalization of each of the theoretical domains.113 The CVR varies from -1.00 to +1.00. A CVR = 0.00 would indicate that half of reviewers considered an item to be essential. For the purposes of this study, we considered a CRV >0 to indicate that an item was essential. All items rated essential were moved forward for interrater reliability; in addition, items for which the majority of the respondents felt that the item was either essential or useful for at least one study design were also moved forward.

## Interrater Reliability

We tested the performance of the item bank by conducting interrater reliability testing. Twelve individuals with varying levels of experience in conducting systematic reviews were asked to use the item bank to independently rate 10 studies that had previously been included in a systematic review of the literature (the relevant information that the rater needed to consider in relation to the study was presented in one article). Articles selected were intended to represent a cross-section of topic areas and risk of bias and precision concerns that can arise in observational studies.114-123 The 10 studies are listed in Table 2. For each study, reviewers were instructed to evaluate all questions included in the item bank in relation to the key questions of the study's original systematic review. The materials provided to reviewers included a copy of the article (study) and summary information from the systematic review including: key questions, key outcomes (benefits and/or harms), any important confounding variables and the conceptual model (analytic framework) included with the review.

Table 2 Studies included in interrater reliability testing

Study | Intervention/Exposure Group Methods | Comparison group? | Study Focus | Mean time needed by rater to review study (Range across raters)^1^
Baker (2002) Functional health literacy and the risk of hospital admission among Medicare managed care enrollees | Prospective cohort | No | Health care delivery | 47 minutes (25-90)
Coleman FH (1990) Safety and efficacy of combined ritodrine and magnesium sulfate for preterm labor: a method for reduction of complications | Retrospective cohort | Yes, prospective cohort | Medication treatment | 51 minutes (20-90)
Crisp AH et al (1992) Long-term mortality in anorexia nervosa. A 20-year followup of the St George's and Aberdeen cohorts | Prospective cohort | No | Disease outcome/harms | 52 minutes (29-70)
Daniel (1999) Effectiveness of community-directed diabetes prevention and control in a rural Aboriginal population in British Columbia, Canada | Prospective cohort | Yes, prospective cohort | Community-based intervention | 63 minutes (25-90)
De Lieto (2003) Immunohistological detection of insulinlike growth factor type 1 receptor and uterine volume changes in gonadotropin releasing hormone analog-treated uterine leiomyomas | Prospective cohort | Yes, prospective cohort | Medication treatment | 43 minutes (20-70)
Fouad et al (1997) A hypertention control program tailored to unskilled minority workers | Prospective cohort | Yes, retrospective cohort | Community, workplace intervention | 51 minutes (20-90)
Hendderson (2006) Pregnancy weight gain and risk of neonatal complications | Case control | Yes | Disease outcome/harms | 44 minutes (15-60)
Kinney TR (1999) Safety of hydroxyurea in children with sickle cell anemia: HUG-KIDS study, a phase l/ll trial | Prospective cohort | No | Medication harms | 39 minutes (25-60)
Schindl (2003) Elective cesarean delivery vs. spontaneous delivery: a comparative experience of birth experience | Prospective cohort | Yes, prospective | Surgery outcomes | 49 minutes (38-60)
van Hamm (1997) Maternal consequences of cesarean section. A retrospective study intraoperative and postoperative maternal complications of cesarean section during a 10-year period | Retrospective cohort | Yes, retrospective | Surgery harms | 44 minutes (17-90)

1 Time estimates were not provided by 2 raters; data presented reflects the mean and range for 10 raters.

Reviewers were asked to complete all questions in a 40-item version of the item bank for each study. The response category for all questions was a multiple-choice format. Because we anticipated that some questions would not be relevant to each study, we included a “not applicable” response category for a number of questions. Reviewers were also encouraged to comment on whether they considered particular questions to be irrelevant for evaluating a study; and to provide descriptive feedback concerning construction of individual questions as well as the instrument overall, including ease of using the instrument to review the study, any study risk of bias, precision, or other quality-related issues that were not captured by the instrument and the time it took to review each study using the instrument.

The study team calculated summary statistics describing agreement between reviewers including mean percent agreement (and associated standard deviation) and first order agreement coefficients (AC1 statistic) for each question in relation to each study and across studies. The AC1 statistic is a summary measure ranging from -1 (when agreement is zero) to 1 (when agreement is 100 percent), that adjusts results for chance agreement and is considered appropriate when there are multiple raters.124 Based on previous work by Walter, Eliasziw and Donner (1998), with 10 raters and 10 articles, we calculated that we had at least 80 percent power to detect that our intraclass correlation is significantly different from zero (based on observed intraclass correlations of 0.2). Appendix A presents background information for calculating the AC1. Fleiss' kappa statistics were initially calculated as measures for summarizing the data but are not presented because of the so-called “paradox” of the kappa statistic where one can have high agreement but low kappa scores,125 raising caution concerning their interpretation.

Because each question included multiple response categories, reliability testing evaluated agreement between raters by comparing the most common response category selected by raters to all other response options for a particular question in relation to each study. Summary statistics by question were calculated across the 12 reviewers and 10 studies. Across all studies, we summarized mean agreement across questions by quality domain and by the two analytic approaches to answering the question (solely determining if specific information is reported in the article or using judgment to evaluate the study's approach to addressing a bias or precision concern). The PIs also reviewed and considered all descriptive comments made by reviewers.

## Post-Test Revisions

Based on face validity, cognitive testing, content validity, and inter-rater reliability testing, we either added, deleted, or revised questions (including question syntax, response categories, and instructions). We elected to revise questions when comments elicited during each phase of testing suggested a need for changes to the question, response categories, or instructions.