# Introduction

In the past decade, the number of publications included in PubMed has increased at an average annual rate of nearly 6 percent. In 1998, PubMed recorded 467,364 citations for the year; by 2008, the number was 816,597. This steady expansion in the volume of published literature increases the complexity and variability of literature that policymakers, clinicians, and patients need to evaluate to make informed health care choices. Systematic reviews that compare interventions play a key role in synthesizing the evidence.1 The assessment of the design and conduct of individual studies is central to the endeavor of synthesis. Systematic reviews routinely use assessments of the design and conduct of studies for interpreting results and grading the strength of the body of evidence; they may also use these assessments to select studies for the review, meta-analysis, and for interpreting heterogeneous findings.2

Although well-designed and well-implemented randomized controlled trials (RCTs) have long been considered the gold standard for evidence, they frequently cannot answer all relevant clinical questions. RCTs may be unethical,3 limited in their ability to address harms because of limited size or length of followup,4 or lack of applicability to vulnerable subpopulations.5 Studies with other designs—such as quasi-experimental studies that mimic RCT design features with the exception of randomization and observational studies that lack randomization, allocation concealment, blinding of participants and interventionists, and in some instances, control groups— may fill these gaps, but the tradeoff is a wider range of sources of bias, including biases in selection, performance, detection of effects, and attrition; these biases have the potential to alter effect sizes unpredictably.6,7 The evaluation of these studies requires validated tools to assess the likelihood of bias.

Critical appraisal of study methodology and terminology has varied and is evolving: overlapping terms include quality assessment, assessment of internal validity, risk of bias, and evaluation of study limitations, but a central construct is the believability of the findings. We elect to use the term “assessment of risk of bias and precision” as the most representative of our goals. The purpose of the assessment of bias and precision is to evaluate the degree to which the effects reported by the study represent the “true” causal relationship between exposure and outcome, that is, the accuracy of the estimation. Rothman et al. note that the accuracy of an estimate depends upon its validity (the absence of bias or systematic error) and precision (the absence of random error).8

A thorough assessment of threats to the validity and precision of an estimate is critical to understanding the believability of a study. Validity can be improved by reducing bias in selection, performance, detection, measurement, attrition, and reporting, and by adequately addressing the role of confounders. Precision can be improved by increased study size and improved study efficiency.

Table 1 presents a taxonomy of threats to validity and precision and draws upon two well-cited sources: the Cochrane Handbook for Systematic Reviews of Interventions7 and Modern Epidemiology.8 This particular taxonomy does not, however, represent the universe of ways in which sources of bias can be classified. Confounding, for instance, is often separately evaluated from selection bias.

Table 1 Threats to precision and validity^*^

Threats | Definition
Threats to precision (random error)
Inadequate study size | -
Lack of study efficiency | Absence of needed stratification in design. When confounding and effect modifiers do not exist, an equal apportionment ratio between exposed and unexposed is the most efficient design. Comparisons within strata may be required to account for known confounders and effect modifiers. Matching on stratification variables allows for an efficient design.
Threats to validity (systematic error)
Selection bias | Systematic differences in baseline characteristics of the groups that are compared (for multiple-arm studies) or within the group (for single-arm or cross-sectional studies).e.g. from self-selection of treatments, physician-directed selection of treatments, or demographic characteristics, failure to account for intention-to-treat clinical, or social characteristics. Includes confounding from differential selection before exposure and disease as well as selection bias where exposure and/or disease influence the selection of the participants
Performance bias | Systematic differences in the care provided to participants in the comparison groups other than the intervention under investigation (for multiple-arm studies) or within groups (for single-arm and cross-sectional studies), e.g., variation in delivery of the protocol, difference in co-interventions, inadequate blinding of providers and participants (variation unlikely in observational studies)
Attrition bias | Systematic differences among the comparison groups in the loss of participants from the study (for multiple-arm studies) or within groups (for single-arm and cross-sectional studies) and how they were accounted for in the results, e.g., incomplete followup, differential attrition
Detection bias | Systematic differences in outcomes assessment among the comparison groups(for multiple-arm studies) or within groups (for single-arm and cross-sectional studies, e.g., inadequate assessor blinding, differential outcome assessment)
Reporting bias | Systematic differences between reported and unreported findings, e.g., differential reporting of outcomes or harms, potential for bias in reporting through source of funding
Information bias | Systematic differences caused by measurement errors, e.g., recall bias

* From Rothman et al., 2003^8^ and Higgins et al., 2006.^7^

Several reviews of critical appraisal tools have found no gold standard.9-12 Deeks and colleagues undertook an extensive review of quality appraisal tools of nonrandomized studies. Of 213 identified tools, only 6^13-18^ meet their criteria of evaluating 6 core elements of internal validity (creation of the intervention groups, comparability of the groups at the analysis stage, allocation to intervention, similarity of groups for key prognostic characteristics by design, identification of prognostic factors, and the use of case-mix adjustment) and were specifically designed for use in systematic reviews.10 These tools vary on their coverage of important criteria10 and vary in their focus on reporting or methods description (that is, questions regarding whether or not the authors reported a particular element of the study in a manuscript) versus judgment of risk of bias (that is, questions regarding whether the conduct of the study altered the believability of the results).

Some current tools such as the Newcastle Ottawa14 are scales that use an implicit weighting. The use of uniform weights may be difficult to justify in all contexts;7 for a particular topic, a single flaw might substantially increase risk of bias, but the use of uniform weights would prevent that determination. Additionally, these tools may require modification or may not be applicable for specific designs such as cross-sectional or case series.15 Also, use of terms such as “adequate” and “appropriate” without adequate guidance may result in differences in interpretation within teams working on the same systematic review. In practice, the idiosyncrasies of topics require and often result in each new review developing its own risk of bias rating tool. These tools may not have adequate instruction for reviewers, leading to inconsistent standards within and across reviews.

Our objective was to create a practical and validated item bank for evaluating the risk of bias of observational studies of interventions or exposures that: (1) captures all of the domains critical for evaluating this type of research; (2) is comprehensive and can be easily lifted “off the shelf” by different researchers; (3) can be adapted to different topic areas and study types (e.g., cohort, case control, cross-sectional and case series studies); and (4) provides sufficient instruction to apply the tool to varied topics. Our risk of bias and precision assessment item bank provides a means to assess the extent to which a study's conclusions can be trusted and identify threats to the accuracy of an estimate.

The item bank is applicable to:

- studies of interventions or exposures and is not designed to evaluate diagnostic studies;
- a variety of observational study design types studies, such as cohort and case-control designs, case series, and cross-sectional designs;
- evaluating internal validity only and does not evaluate external validity (applicability).

Our item bank is appropriate for studies that lack random allocation to an intervention and rely on association between changes or differences in exposure or intervention and changes or differences in an outcome of interest.19 Applicable designs include studies with controls (cohort and case-control) as well as studies without controls that rely on changes or differences in exposure (cross-sectional and case series).20 We focused on these specific designs as common examples of observational studies. Although we did not test the reliability of our item bank for other designs, we note that the item bank may be used for other designs as well, with some modifications. For instance, quasi-experimental studies will need to add, in addition to the questions selected from our item bank, questions from RCT appraisal tools on allocation concealment and blinding of patients and interventionists.

The intent of the item bank is to serve as a comprehensive source of questions that have been validated and tested. We anticipate that principal investigators will select specific items based on the needs of the review topic. The specific choice of items for a review will depend upon the potential sources of bias in the studies included for that topic.

## Approaches To Assessing the Risk of Bias and Precision of Studies

As noted by Deeks et al., approaches to evaluating the quality of observational studies focus on either the evaluation of bias or on “methods description,” that is, the evaluation of the “objective characteristics of each study's methods as they are described by the primary researchers” (Deeks et al., p. 23).10 Study appraisal based on risk-of-bias lists potential sources of bias (Table 1), relies heavily on judgment, and is supported by transparency in recording the judgment. One constraint of this approach is that threats to validity and precision can occur at various points in the study. Assessing these threats without explicit reference to methods used at each stage of research would require a relatively abstract evaluation and could result in poor interrater reliability. The latter approach of “methods description” is easier to implement because methods for each stage of research tend to correspond well with how manuscripts are written. This approach relies less on judgment10 but may fall short of evaluating believability. One solution is to use both approaches, using the methods description for each stage of research as the primary framework to facilitate ease of review, but clearly specifying how the design and conduct of the study at that stage addresses threats to validity and precision. This approach allows some degree of reliance on reporting of results as well as judgment on the part of the reviewer. Our proposed item bank began with this approach to identify questions relevant to each of the 12 domains identified by Deeks et al.: (1) background/context, (2) sample definition and selection, (3) interventions/exposure, (4) outcomes, (5) creation of treatment groups, (6) blinding, (7) soundness of information, (8) followup, (9) analysis comparability, (10) analysis outcome, (11) interpretation, and (12) presentation and reporting.10 Abstractors review a manuscript primarily to identify sources of bias but look to identify this information in the order that information is typically presented in a manuscript.

## Organization of the Manuscript

The remainder of this manuscript describes the methods used in compiling, validating, and testing the reliability of the item bank, followed by results and discussion.