# Content Validity Experts

Wendy Bruening, Ph.D.

ECRI Institute

Plymouth Meeting, PA

Marie Griffin, M.D., M.P.H.

Vanderbilt University

Nashville, TN

Susanne Hempel, Ph.D.

RAND

Santa Monica, CA

Eric Johnson, Ph.D., M.P.H.

Kaiser Permanente Northwest

Portland, OR

Mark Oremus, Ph.D.

McMaster University

Hamilton, ON

Jodi Segal, M.D., M.P.H.

Johns Hopkins University

Baltimore, MD

Tatyana Shamliyan, M.D., M.S.

University of Minnesota

Minneapolis, MN