# Cognitive Testing Respondents

Susanne Hempel, Ph.D.

RAND Corporation

Santa Monica, CA

Rebecca Jerome, M.L.I.S., M.P.H.

Vanderbilt University

Nashville, TN

Dan Jonas, MD, M.P.H.

University of North Carolina at Chapel Hill

Chapel Hill, NC

Jennifer Kraschnewski, M.D.

University of North Carolina at Chapel Hill

Chapel Hill, NC

Michael Matheny, M.D., M.S., M.P.H.

Vanderbilt University

Nashville, TN

J Nikki McKoy, M.P.H.

Vanderbilt University

Nashville, TN

Melissa McPheeters, M.P.H., Ph.D.

Vanderbilt University

Nashville, TN

Sandra Micucci, M.Sc.

Vanderbilt University

Nashville, TN

Brett Nishikawa, M.D.

University of North Carolina at Chapel Hill

Chapel Hill, NC