# Peer Reviewers

Jesse Berlin, Sc.D.

Johnson & Johnson Pharmaceutical

Research and Development

Raritan, NJ

Olaf M Dekkers, M.D., Ph.D.

Leiden University Medical Center

Leiden, Netherlands

Mark Helfand, M.D., M.P.H., M.S.

Oregon Health & Science University

Portland, OR

Robert Kane, M.D.

University of Minnesota

Minneapolis, MN

P. Lina Santaguida, Ph.D.

McMaster University

Hamilton, ON

Jonathan Treadwell, Ph.D.

ECRI Institute

Plymouth Meeting, PA