# Technical Expert Panel

Wendy Bruening, Ph.D.

ECRI Institute

Plymouth Meeting, PA

Tim Carey, M.D.

University of North Carolina at Chapel Hill

Chapel Hill, NC

Michael Handrigan, M.D.

Agency for Healthcare Research and Quality

Rockville, MD

Marie Griffin, M.D., M.P.H.

Vanderbilt University

Nashville, TN

Katherine Hartmann, M.D., Ph.D.

Vanderbilt University

Nashville, TN

Susanne Hempel, Ph.D.

RAND

Santa Monica, CA

Eric Johnson, Ph.D., M.P.H.

Kaiser Permanente Northwest

Portland, OR

Robert Kane, M.D.

University of Minnesota

Minneapolis, MN

Susan Norris, M.D., M.Sc.

Oregon Health and Science University

Portland, OR

Mark Oremus, Ph.D.

McMaster University

Hamilton, ON

Maria Ospina, M.Sc.

University of Alberta

Edmonton, Alberta

Karen Schoelles, M.D.

ECRI Institute

Plymouth Meeting, PA

Jodi Segal, M.D., M.P.H.

Johns Hopkins University

Baltimore, MD

Tatyana Shamliyan, M.D., M.S.

University of Minnesota

Minneapolis, MN

Jonathan Treadwell, Ph.D.

ECRI Institute

Plymouth Meeting, PA

Paul Shekelle, M.D., Ph.D.

RAND Corporation

Santa Monica, CA