# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Carla Bann, Mey-Tzy Kuo, Kathleen Lohr, Loraine Monroe, and Elizabeth Tant.