# Discussion

With the increasing use of observational studies in evidence synthesis, systematic reviewers have a greater burden of evaluating risk of bias and precision to identify the effects of these potential concerns on study results. The evaluation of study risk of bias and precision is essentially a subjective exercise, requiring judgments by a reviewer. Nonetheless, this exercise is the only means of evaluating the degree to which a study's results can be believed and is a critical step on the pathway to evaluating the strength of a body of evidence. Our item bank builds on and extends the efforts of previous instruments to (1) create an evaluation tool that is specifically designed to work within the larger context of systematic review methodology and tasks; (2) explicitly focus on believability of the study rather than applicability; (3) comprehensively consider the elements that support believability; and (4) promote transparency and consistency of judgment between pairs of reviewers working on a single review and across reviews, particularly when customization is needed for the specific topic.

Our item bank is intended to be used to interpret the believability of individual studies, but just as importantly, to create building blocks for evaluating the risk of bias and precision for the body of evidence. Systems to grade the strength of a body of evidence such as GRADE and the AHRQ strength of evidence approach use an overall assessment of risk of bias as one key element; other separate elements include applicability and precision. Commonly used instruments such as the Newcastle Ottawa scale14 and Downs and Black15 include questions on all three areas: risk of bias, precision, and external validity (applicability) within their ratings for individual studies. These instruments identify questions that evaluate external validity but not questions related to precision. When all these items are included within a rating scale, as in the Newcastle Ottawa scale, the results cannot be used as components for judging the strength of the body of evidence without some manipulation: the external validity and precision elements need to be removed from the overall scores to isolate the risk of bias for a study.

Our item bank focuses explicitly on believability, that is, risk of bias and precision. It excludes applicability entirely. It includes questions on precision to allow for a variety of approaches to analysis. Systematic reviews that rely on meta-analyses may not need to evaluate study-specific elements of precision, particularly sample size and appropriate statistical analysis. Systematic reviews that cannot pool estimates because of heterogeneity of results may choose to include evaluations of precision in addition to risk of bias. The item bank identifies the precision questions clearly so that reviewers can judge whether or not to evaluate those elements.

Table 4 Item bank questions mapped to risk of bias, precision, and methods domain

Methods Domain | Precision | Selection Bias/ Confounding | Performance Bias | Attrition Bias | Detection Bias | Reporting Bias | Information Bias | Overall believability | Total N of items
Background/ context | - | - | - | - | - | - | - | - | 0
Sample definition and selection | - Q6 (CH, CC, CS, XS) | - Q1 (CH, CC, CS); - Q2 (CH, CC, CS, XS); - Q4 (CH, CC) | - Q1 (CH, CC, CS); - Q5 (CH, CC) | - | - Q1 (CH, CC, CS) | - Q1 (CH, CC, CS) | - Q3 (CH, CC, CS, XS) | - | 6
Interventions/ exposure | - | - | - Q7 (CH, CC, CS, XS) | - | - | - | - | - | 1
Outcomes | - | - | - | - | - | - Q8 (CH, CC, CS, XS) | - | - | 1
Creation of treatment groups | - | - Q9 (CH, CC); - Q10 (CH, CC) | - Q11 (CH, CC, CS, XS); - Q12 (CH, CC, CS, XS) | - | - | - | - | - | 4
Blinding | - | - | - | - | - Q13 (CH, CC, CS, XS) | - | - | - | 1
Soundness of information | - | - | - | - | - | - | - Q14 (CH, CC, CS, XS); - Q15 (CH, CC, CS, XS) | - | 2
Follow-up | - | - | - | - Q16 (CH, CC); - Q17 (CH, CC, CS); - Q18 (CH, CC, CS); - Q19 (CH, CC) | - | - | - | - | 4
Analysis comparability | - | - Q20; - Q22 (CH, CC, CS, XS) | - | - | - | - | - Q21 (CH, CC, CS, XS) | - | 3
Analysis outcome | - Q25 (CH, CC, CS, XS); - Q27 (CH, CC, CS, XS) | - | - | - Q23 (CH, CS) | - | - Q24 (CH, CC, CS, XS); - Q26 (CH, CC, CS, XS) | - | - | 5
Interpretation | - | - | - | - | - | - | - | - Q28 (CH, CC, CS, XS) | 1
Presentation and reporting | - | - | - | - | - | - Q29 (CH, CC, CS, XS) | - | - | 1
Total^*^ | 3 | 7 | 5 | 5 | 2 | 5 | 4 | 1 | 29

* number of items sum to greater than total number of items because some items relate to multiple risks of bias;

CH=cohort; CC=case-control; CS=case series, XS=cross-sectional; N=number

Our item bank includes nearly all the domains and elements for evaluating observational studies identified by West et al.,9 in one of three ways: within questions, within response categories to the questions, or within instructions to interpreting the questions. We did not include two elements from the West et al. list of evaluation requirements within our item bank: (1) the study includes clearly focused and appropriate questions and (2) use of concurrent controls. We judged, in consultation with our technical experts and other users, that the former question is not relevant to evaluating bias and precision; our intent is to judge the believability of study results that are relevant to the goals of the systematic review rather than to its own intent. We did not include the latter question because we consider the issue of concurrent controls as a matter of design. The intent of our item bank is not to evaluate the believability of study results based on the type of study design used, rather, we intend for responses to the items in the bank to identify design features (or the lack of features) that could increase the risk of bias.

The wide array of designs and associated risks of biases in observational studies imply that systematic reviewers will need to customize their review form to concentrate on the most critical selection of items for the topic at hand and establish minimum standards for addressing these items. An important contribution of this instrument is that we provide choices through a comprehensive array of items rather than a fixed menu of required elements through an instrument. We provide instruction to teams (with separate instructions to scientific leads and other team members) where customization may be required.

We note the overall low interrater reliability scores we obtained through our testing: one likely reason is that we did not develop instructions for each of the studies on how to customize standards for that particular review. By design, our goal was to document experience using the item bank on a broad range of studies. Our results are also limited by this range: unlike typical systematic review teams that share a common understanding of a single review topic, our raters, themselves with varied backgrounds, were asked to rate studies for 10 different topics.

Although content experts may see value in evaluating multiple nuances related to threats to bias, the detailed consideration of each of those concerns may not always be practical. Our reviewers took an average of approximately 48 hours to complete the 10-study risk of bias and precision review. Instead, a more practical approach is to identify the most critical threats to validity and precision in a body of evidence and then select questions, perhaps no more than 10–15, that can evaluate the concern.

Next steps in evaluating this item bank include the identification of specific biases for which different study designs are most at risk. This exercise will help to identify a core set of questions can be identified that must be used consistently across studies. A second area for research is the assessment of customized questions (that is, the selection of items and standards for specific items) and inter- and intrarater reliability for teams of reviewers working on the same topic. A key consideration in such testing will be the selection of studies with known serious issues in design (such as the selection of prevalent users rather than new users) in order to assess the ability of the instrument to identify potential sources of bias. A third urgent task is to evaluate the empirical basis for each item by measuring the correlation between responses to specific items and effect sizes as means of further culling the item bank.

Our item bank can be used in a variety of systematic reviews as further development of the item bank continues. Although it does not include questions on adequacy of randomization generation, concealment of allocation, and blinding of participants and interventionists because these items are specific to RCTs, many questions in our item bank apply to RCTs as well. From a practical perspective, systematic reviews that include RCTs as well as non-RCT designs may find it useful to evaluate all study designs with the same questions in order to reduce variability for those items. It will also permit a direct comparison on these items between RCTs, nonrandomized and observational studies. The generation of resulting data may be able to help with a critical question when considering resource allocation for research: when are RCTs essential for answering research gaps?