# Item Bank for Assessment of Risk of Bias and Precision for Observational Studies of Interventions or Exposures

This item bank is intended to evaluate the quality of studies examining the outcomes of interventions, treatments, or exposures. Eligible study designs include observational studies (cohort studies, case-control, case-series, and cross-sectional studies). Some questions may be applicable to quasi-experimental designs. It is not intended to rate the quality of studies concerning the accuracy of diagnostic tests. Abstractors can use the empty text box included with each question to document an explanation of their rating for later review. This may be particularly helpful in relation to a “cannot determine” response choice.

Sample Definition and Selection