# Appendixes

Appendix A AC1 Statistic

Appendix B Item Bank for Assessment of Risk of Bias and Precision for Observational Studies of Interventions or Exposures