# Types of NFCOI

No taxonomy exists for NFCOIs. Interests relating to the individual (intellectual, professional, career advancement), persons with whom the individual has a close personal relationship (e.g., family members, partners, friends, colleagues), and the employer or organization with which the index person is affiliated (e.g., employer, academic institution, specialty organizations, other professional organizations, and community interests) all tend to overlap somewhat. Nonetheless, this hierarchy offers an approach to identifying and categorizing NFCOI, described below, related to interests of (1) the individual through personal beliefs, (2) others through personal relationships, and (3) the institution through institutional relationships. Interests related to career advancement, a fourth type of NFCOI, draw upon the interests of the individual, others with a personal relationship with the individual (such as mentors), and the institution.