# References

1 Report to the President and the Congress on Comparative Effectiveness Research. U.S. Department of Health & Human Services. 2012. www.hhs.gov/recovery/programs/cer/execsummary.html. Accessed 5-7-12.
2 Westfall JM, Mold J, Fagnan L. Practice-based research—”Blue Highways” on the NIH roadmap. JAMA. Jan. 24. 2007;297(4):403-6. [pmid: 17244837].
3 Bekelman JE, Li Y, Gross CP. Scope and impact of financial conflicts of interest in biomedical research: a systematic review. JAMA. Jan. 22–29. 2003;289(4):454-65. [pmid: 12533125].
4 Jorgensen AW, Maric KL, Tendal B, et al. Industry-supported meta-analyses compared with meta-analyses with non-profit or no support: differences in methodological quality and conclusions. BMC Med Res Methodol. 2008;8:60. [pmid: 18782430].
5 Lundh A, Sismondo S, Lexchin J, et al. Industry sponsorship and research outcome. Cochrane Database Syst Rev. 2012;12:MR000033. [pmid: 23235689].
6 U.S. Government Printing Office. Proposed Rules. Federal Register. August. 24. 2011;76(164):52918-929.
7 Institute of Medicine. Conflict of Interest in Medical Research, Education, and Practice. Washington, DC. The National Academies Press. 2009.
8 Oregon Evidence-based Practice Center. Policy on Conflicts of Interest re: Work on the Drug Effectiveness Review Project. Oregon Evidence-based Practice Center. 2001.
9 Institute of Medicine. Finding What Works in Health Care: Standards for Systematic Reviews. Washington, DC. The National Academies Press. 2011.
10 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011.
11 Subtitle D-Patient-Centered Outcomes Research. Public Law 111–148, Statute Number:124 STAT. 727, Section:6301. March. 23. 2010.
12 National Institute for Health and Clinical Excellence. A Code of Practice for Declaring and Dealing With Conflicts of Interest. London. National Institute for Health and Clinical Excellence. 2007.
13 Gøtzsche PC, Ioannidis JPA. Content area experts as authors: helpful or harmful for systematic reviews and meta-analyses?. BMJ. 2012;345:e7031. [pmid: 23118303].
14 Chang SM. Recent rapid responses re: content area experts as authors: helpful or harmful for systematic reviews and meta-analyses?. 2012. www.bmj.com/content/345/bmj.e7031/rr/613262. Accessed November 28, 2012.
15 Krimsky S. Autonomy, disinterest, and entrepreneurial science. Society. May/June. 2006;43(4):22-9.
16 International Committee of Medical Journal Editors. ICMJE Form for Disclosure of Potential Conflicts of Interest. 2009. www.icmje.org/coi_disclosure.pdf. Accessed May 7, 2012.
17 Kesselheim AS, Wang B, Studdert DM, et al. Conflict of interest reporting by authors involved in promotion of off-label drug use: an analysis of journal disclosures. PLoS Med. Aug. 2012;9(8):e1001280. [pmid: 22899894].
18 P. LoS Medicine Editors. Does conflict of interest disclosure worsen bias?. PLoS Med. 2012;9(4):e1001210. [pmid: 22545026].
19 Loewenstein G, Sah S, Cain DM. The unintended consequences of conflict of interest disclosure. JAMA. Feb. 15. 2012;307(7):669-70. [pmid: 22337676].
20 The PLoS Medicine Editors. Making sense of non-financial competing interests. PLoS Med. Sep. 30. 2008;5(9):e199. [pmid: 18828670].
21 Public Responsibility in Medicine and Research (PRIM&R). 2011 PRIM&R Conflict of Interest Policy. Personal communication. 2006.