# Next Steps

Many questions remain unanswered in this underevaluated area of research conduct. The first and most basic questions relate to the incidence and impact of NFCOI: When NFCOIs have been identified in the past, in what category do they typically occur? To what degree has NFCOI affected the conduct of reviews in the past? Such research needs to involve both literature review as well as surveys of researchers and EPC administrators.

A second set of questions relates to the utility of the proposed NFCOI guidance in this document. Do peer reviewers, funders, principal investigators, team members, and users of reports find additional NFCOI guidance of use in identifying NFCOI and mitigating the risk of bias from NFCOI? How does the influence of NFCOI compare with that of FCOI?

A third area of investigation relates to implementation. Any attempted implementation of the questions proposed in the document requires evaluation of respondent burden, variation in interpretation of the questions relating to identifying NFCOI, and the extent of differences of judgment on appropriate management strategies within review groups and between review groups and funders. A better understanding of the barriers to implementation can help to fashion appropriate dissemination strategies of future guidance. Another concern is how to jointly manage FCOI and NFCOI: we recognize that overlap exists between FCOI and NFCOI policies, as discussed above. Ongoing communication between groups addressing FCOI and NFCOI policies will help.