# Introduction

Clinicians and patients regularly face important health care decisions without adequate information.1 Systematic reviews (SRs) serve a critical role in ensuring that health care decisions are evidence based. In doing so, they ensure that the recommended care is given “to the right patient at the right time, resulting in improvement in that patient’s health.”2 SRs summarize and synthesize large and sometimes contradictory research results, clarify their implications for diverse stakeholders, account for variations in the risk of bias of individual studies when interpreting results, compensate for lack of power in individual studies through pooling, and identify findings relevant to populations, and subgroups of interest. To meet all these goals, SRs must be credible.

Rigorous methods and consistent application of standards lay the foundation for ensuring the credibility of SRs, but are not sufficient. An unavoidable component of SRs is the role that judgment plays in the framing of research questions, the selection and application of methods, the conduct of the specific research steps, and the interpretation of the results. Research has shown that financial conflicts of interest (COI) can threaten the internal and external validity of primary studies as well as SRs.3–5 Conflicts may go well beyond the financial: strongly held beliefs (personal or professional) and the desire for academic recognition or advancement can also bias the conduct or reporting of SRs.3 These issues, which fall under the umbrella of nonfinancial conflict of interest (NFCOI), are the focus of this document, specifically as they apply to SR team members. The guidance in this document does not address NFCOI for other participants in the review process, such as Technical Expert Panel members, stakeholder groups, and peer reviewers. Some stakeholders or Technical Expert Panel members may be selected specifically for particular professional or personal perspectives that could be considered COI, and efforts must be made to identify and balance these perspectives. We view potential NFCOI issues within the SR team to be quite separate, and because such issues are not often considered, we believe it is all the more important that guidance be provided on their management.

Prominent organizations involved in the production of SRs take different approaches in addressing COI (Appendix A). Many organizations tend to focus on financial COI (FCOI); such conflicts are considered to be easier to assess in objective terms because they are quantifiable and easier to mitigate.6–8 Other organizations describe NFCOI in vague terms such as “personal association,” “professional or intellectual bias,” or “other” conflicts, but provide little guidance on how to identify, assess the severity of, and manage the NFCOI.9–12

The purpose of this document is to (1) define NFCOI as it applies to SR teams, (2) create practical suggestions for SR teams, through examples, about how to identify, characterize, and manage NFCOI, and (3) improve transparency of judgment regarding NFCOI for users of reviews. Given the lack of evidence in this area, we believe that any list of NFCOI rules for all circumstances would be arbitrary. Our intent, therefore, is not to create absolute standards; rather, we intend to offer users an approach for recognizing NFCOIs and addressing them. This document also aims to engage the community in further discourse on this vital issue. This work is exploratory: As the approach is implemented, its feasibility, burden on investigators, and impact on reducing risk of bias should be concurrently assessed.

We do not believe that the presence of NFCOI implies professional misconduct on the part of the individuals who disclose these circumstances. Our work builds on the premise that NFCOI needs to be evaluated in the context of each review. A given faculty or staff member who may have NFCOI for one topic may have no NFCOI for other review topics. The disclosure of conflicts does not inevitably lead to punitive action, nor should it be viewed as requiring such action.

Anticipated users of this guidance include the Agency for Healthcare Research and Quality (AHRQ), the Evidence-based Practice Centers (EPCs) funded by AHRQ, organizations with similar interests (e.g., Institute of Medicine [IOM], the Cochrane Collaboration, the Patient-Centered Outcomes Research Institute [PCORI]), other SR teams, and SR users. This guidance may be of particular interest to organizations sponsoring SRs that have audiences with competing interests. Taxpayer-funded reviews, in particular, have an obligation to meet the needs of a broad audience and must be particularly sensitive to the risk of bias. We believe that when funders establish and maintain clear and consistent standards for disclosure and management of NFCOI, public confidence in the products is improved.

This document focuses on the management of competing concerns, that is, ensuring adequate clinical or content expertise on SR teams while maintaining independence of judgment. Clinical and content expertise, in our view, can arise from a broad range of clinical, practice, and research experience and is not a term reserved solely for experts whose primary research will be included in the SR. By clinical expertise we refer to expertise gained from patient care for a specific clinical area. For nonclinical topics, content expertise may arise from research or practice in the substantive concerns of the field. Our view is that such clinical and content expertise is vital to interpreting the evidence appropriately and framing the discussion in terms of decisional dilemmas. Our approach contrasts with that of Gøtzsche and Ioannidis, who advocate that SRs exclude “content area experts” by default:13 we anticipate that a balance between scientific rigor and utility will require the involvement of methodologists as well as content and clinical experts.14 On the other hand, our perspective is distinct from that suggested by Krimsky, who proposes that intellectual interests cannot be separated from the scientific enterprise, are generally a matter of public record, and “a scientist’s propensity toward one theory or another can be discussed and addressed in open communication with the scientific community.”15 In our view, SRs, unlike primary research, require the interpretation and synthesis of studies for an entire body of evidence that may be based on a variety of theories. Because SR teams and expert panels consist of a limited number of individuals, a small number of investigators or experts sharing a common interest could guide the review in a biased direction and open communication with the scientific community may not suffice to correct this bias. Our approach seeks to mitigate the risk of bias while ensuring clinical utility and relevance for decisionmaking.