# Identifying, Measuring, and Managing NFCOI

Based on workgroup discussions, we identified five key steps, described in greater detail below, for identifying, measuring, and managing NFCOI: (1) identify context-specific issues, (2) identify and disclose NFCOI, (3) assess the degree to which the potential for undue influence from NFCOI exists, (4) manage NFCOI that has the potential to unduly influence the SRs, and (5) monitor and report NFCOI regularly.

## Identify Context-Specific Issues

Context-specific concerns that raise the potential for NFCOI include topics with intense advocacy, active policy debate, large interspecialty variations, and limited availability of clinical or content expertise (as in the case of small fields such as the study of rare diseases). These situations do not automatically give rise to NFCOI, but they raise the risk of NFCOI. The process of identifying the context helps to narrow the potential range of remedies: topics with high context-specific stakes may require greater attention to the composition of the SR team to include a more diverse set of participants or even exclude all participants with NFCOI. These circumstances are particularly pertinent for comparative effectiveness research, where multiple active treatments may be compared in a heated policy environment. We note, however, that the absence of context-specific issues (e.g., no strong advocacy position, no active policy debate) does not imply that NFCOI cannot occur; rather, it presents a wider range of options for managing NFCOI that does occur.

### Advocacy/Policy Positions

Although SRs are typically commissioned in response to uncertainty about clinical or policy questions, areas in which such uncertainty has spawned intense advocacy or policy debate have a higher risk of NFCOI. People involved in setting or influencing policy with stated positions can be biased because findings from an evidence report may impact their policy agenda. Likewise, organizations for which people work, of which they are members, or with which they are affiliated can have stated positions on Key Questions being posed in a comparative effectiveness review (CER). A person involved in such an organization might be, or might appear to be, conflicted when asked to be involved as a SR team member or expert panelist.

If the person is conflicted between loyalty to the stated position and providing unbiased work on the project, then the Key Questions generated, literature search strategy, inclusion and exclusion criteria, study selection, definition of outcomes, analysis strategies, or interpretation of results may contribute to the report being biased towards his/her preconceived notion (Exhibit 1).

Exhibit 1 Examples of advocacy/policy positions

##### Example 1, Personal Position

A national health system is advocating the implementation of the primary care medical home model. AHRQ commissions an SR about the effectiveness of this model. The SR team seeks a senior administrator from the health system who has a background in health services research and who has been charged with regional implementation of the medical home program to serve as a team member. As a team member, she urges a broad definition of primary care practice organization and management, and inclusion of studies aimed at specific components of practice change, with the net effect of including a large number of favorable studies of marginal applicability. Hence, the resulting report seems to be more supportive of these sorts of interventions, albeit with a lower strength of evidence than might have been found using a narrower view of the intervention.

##### Example 2, Affiliated Organization Position

A State neurology society has a position statement saying that medications for restless leg syndrome are ineffective and have no place in therapy. Dr. Archibald is the president-elect for the society but not an author of their position paper. He is asked to be an SR team member on a project looking into the comparative effectiveness of medications for restless leg syndrome versus supportive care alone. Dr. Archibald does not hold a strong personal opinion about the benefits and risks of medications for restless leg syndrome, but he is conflicted. Becoming president is the culmination of several years of hard work. He would feel uncomfortable if the results of the report were contrary to the organization’s position paper. Given his knowledge of the literature, he knows that studies looking at one symptom scoring scale show medications to be effective while studies using another scale do not show evidence of effectiveness, but both scales are valid and commonly used, but have different strengths and weaknesses. He persuades the SR team (given his neurology experience and stature in the neurology community) to use one scale exclusively. The report subsequently finds no benefits are derived from the use of medications for restless leg syndrome.

### Interspecialty Variations in Practice

Patient-centered outcomes research not only examines head-to-head trials of drugs and devices, but also considers the effects of systems of care on health care outcomes. The U.S. health care system is complex: the cost, quantity, and quality of care vary by geographic region and type of provider. For the same clinical problem, multiple diagnostic approaches and treatment alternatives may exist, and particular type of provider or specialty may favor each. Patients, insurers, and policymakers want to know the most effective type (or types) of treatments to use for a given clinical problem. Quite apart from financial conflicts with the practice of a particular approach under review, if a review author is trained and experienced in a certain specialty, this training can result in a perspective that may lead to an unconscious bias because the author is familiar with and trusts a particular approach more than other approaches (Exhibit 2).NFCOI may arise simply because providers have professional pride in delivering the “best” care.

Exhibit 2 Example of interspecialty variations

Patients with low back pain may seek care from a variety of providers, including allopathic specialists (orthopedic surgeons, physical medicine and rehabilitation, neurologic surgeons, rheumatologists), osteopathic physicians, doctors of chiropractic, and physical therapists. Descriptive research has shown that the types of treatments and their costs vary substantially across these specialties. Multiple studies, including large cohort studies, secondary data analyses, and some trials, have examined both cost and functional status outcomes. The review question is to compare the clinical outcomes in acute and subacute back pain when treatment is initiated with one of the above providers. The review team includes neurosurgeons only and comes to very different conclusions from a concurrent review that included multiple provider types as well as spine surgeons.

### Limited Availability of Clinical or Content Expertise

Small fields such as the study of very rare diseases are often characterized by a small pool of experts and limited funding sources. Particularly in complex areas such as rare metabolic conditions or very rare cancers, patients are treated by one of a small number of specialists, typically at academic medical centers. With such rare conditions, one source of research funding, often a pharmaceutical company, is not unusual; and only one treatment is often available. In this scenario, the ability to obtain even a small amount of funding is intensely competitive and requires substantial collaboration among investigators to conduct studies of adequate size. Thus, researchers and funders tend to work in a highly integrated way, investigator perspectives are well known and investigators place a high premium on the ability to collaborate across groups of patients.

In a small field where “everyone knows everyone,” dependence for nontangible support such as letters for promotion, positive reviews of manuscripts, opportunities to present and future employment, or opportunities to “play” in the field can be substantial (Exhibit 3). Influential investigators may be banking on future success of novel compounds and, thus, may be invested in having their studies reviewed positively. If they have the ability to influence opportunities for individuals participating in the review, conflict can arise. These conditions combine to make it difficult to compose an SR team without COI yet knowledgeable about the subject matter.

Exhibit 3 Example of limited availability of clinical expertise in the field

An SR of a condition that affects fewer than 4,000 individuals in the country is conducted. The condition is debilitating if not treated, and a new drug has been approved, based on two fairly small randomized controlled trials. Other drugs are in the pipeline and early research is available on some compounds. The pharmaceutical company that produced the drug funds almost all research in the field and their scientists are major players at scientific meetings. All patients are treated at a limited number of specialist clinics, mostly at academic centers. All clinics are engaged at some level of research, at minimum by enrolling patients in the drug trials. The community of scientists engaged in this work and seeing patients is very small and they all know one another. They are all aware that, as researchers of a rare disease, their access to government funding is challenging, and they feel a strong solidarity based on their perceived lack of attention in the larger clinical research arena. They also serve as strong advocates for their patients, and the family advocacy groups are very connected to the researchers. The SR team includes a clinical staff person who runs a clinic caring for patients with the condition. This individual is the only team member available with direct clinical experience, and has important expertise in a complicated clinical condition, but because all clinics are enrolling patients in the drug trials, the staff member’s name may appear in drug company publications about the drug being reviewed. This individual is salaried and his/her career does not depend on research productivity, but it is possible that the inclusion of the name on the report and on publications related to clinical trials funded by the pharmaceutical company could trigger letters to the editor casting doubt on the SR’s objectivity.

Table 1 provides suggestions for three possible questions for funders and principal investigators to consider in judging context-specific bias.

Table 1 Questions to assess the context for nonfinancial conflicts of interest for systematic reviews

### Identify and Disclose NFCOI

The identification and disclosure of NFCOI requires the selection of appropriate indicators of NFCOI. A potential minimal approach is to ask individuals whether they consider themselves to be at risk of NFCOI. Evidence suggests, however, that individuals do not recognize bias in themselves. Thus, such an approach is insufficient by itself. Disclosure alone is likely to be inadequate, even for FCOI,17 and may even exacerbate bias18 because the individual disclosing the conflict may exaggerate recommendations in anticipation of discounting on the part of the audience, or be explicitly biased because the audience has been warned.19 An additional strategy is to document proxies of bias other than individual self-perception such as previously stated opinions, clinical specialty, or organizational affiliations. We note that these indicators offer no absolute proof of NFCOI. Likewise, the absence of such circumstances does not preclude strongly held beliefs from influencing the investigator’s judgment. Funders and PIs could also search for evidence of NFCOI by reviewing the individual’s publication and internet record. This information might be in the form of opinions in correspondence, blogs, interviews, expert testimony, editorials, or narrative reviews. Other publications such as SRs, policy papers, or clinical practice guidelines may also provide insights into an individual’s competing interests. We note, however, that an exhaustive search through publication and Internet records is likely to be resource-intensive and possibly counter-productive to team relations, and is not likely to produce definitive evidence of the presence or absence of conflicts.

#### Personal Beliefs

Individuals may have strong and unwavering personal beliefs that can introduce bias when evaluating the comparative effectiveness of a treatment. Through decisions on the formulation of Key Questions, literature search strategy, inclusion and exclusion criteria, selection of studies, definition of outcomes, analysis strategies, or interpretation of results, a team member may slant the SR in favor of findings supporting his or her beliefs (Exhibit 4).

Exhibit 4 Example of personal beliefs exerting an undue influence

Ms. Alomar is a nurse practitioner who is asked to work on a project evaluating the comparative benefits and harms of physician assistant care versus nurse practitioner care in patients with hypertension. She attended college for 4 years to become a registered nurse, worked in practice for 5 years, and then went back to school for 2 years to become a nurse practitioner. Upon graduation, she struggled for acceptance in her medical center but has now established a successful primary care practice that sees patients with hypertension. Ms. Alomar believes that physician assistants cannot substitute for the care and nurturing nurses provide, that physician assistants’ training is substandard to provide quality care, and that findings showing that physician assistants provide quality care will harm her and the profession she loves. She is included in the team and does not reveal that the proposed literature search excludes some relevant journals that frequently publish articles by physician assistants; however, she explicitly recommends searching a nursing-specific database. The report finds insufficient information to evaluate the quality of care provided by physician assistants.

#### Personal Relationships

Personal relationships (including those that are adversarial)20 can be a barrier to objective evaluation of the quality and outcomes of research. In addition to direct relationships between investigators and the authors of studies eligible for the review, networks of relationships among family, friends, partners, colleagues, and the authors of the eligible studies may also lead to conflicts. Investigators may face implicit or explicit conflicts between an unbiased evaluation of the evidence and maintaining or promoting these personal relationships, which may not be evident to an external observer. These conflicts can affect their selection of Key Questions, outcomes, and interpretation of results (Exhibit 5).

Exhibit 5 Example of personal relationships as conflicts of interest

Joe Schneider is working on a CER on treatments for breast cancer. Joe is friends with Stuart, an old college roommate who owns a startup company that manufactures Wonderdrug, a new medication to treat breast cancer. Wonderdrug has received substantial media coverage and its commercial business is brisk. Neither Joe nor anyone in his family has financial investments in the company, but Joe is very familiar with the details of Wonderdrug because of conversations with Stuart over the years. Studies of Wonderdrug report favorable remission rates, but one study reports myocardial infarction among women taking Wonderdrug. Studies of other drugs and comparator groups found no similar events. Joe feels that the findings were the result of chance and sees no plausible biological link between the drug and the risk of myocardial infarction. As a senior investigator, his viewpoint influences the other SR team members to ignore myocardial infarction as a harm.

#### Institutional Relationships

An investigator’s institutional role can create a competing interest that makes objective evaluation of studies difficult. The pressure to conform the findings of an SR to the outcome most beneficial for the investigator’s institution may preclude an unbiased evaluation of the evidence (Exhibit 6).

Exhibit 6 Example of institutional conflicts

University A holds a patent for a genetic test included in a CER conducted by the university-affiliated EPC. Members of the review staff are aware of the university-held patent. The CER finds evidence of no difference between the genetic test and comparators on health outcomes. The lead investigator rewrites the conclusions to suggest the need for more research, rather than focusing on the lack of benefit from the test.

#### Career Advancement

The rewards of pursuing academic research include the satisfaction of making contributions to scientific knowledge, affecting people’s well-being, peer recognition, and career advancement. COI and NFCOI could converge when the perception of one’s peers and superiors is a significant consideration in academic promotion and future funding. We note that striving for career advancement is not by itself a competing interest. However, a competing interest may arise if research findings contradict the prevailing opinion in the field and if the conclusions of an SR could be negatively perceived by peers whose opinions and evaluations play a role in one’s academic advancement. Thus, a researcher may review the evidence in a biased manner if his or her career may be impacted by peers’ perceptions of the SR’s conclusions. A further difficulty is that this conflict is likely to be post hoc, i.e., the conflict arises when the evidence is summarized and may not be known a priori (Exhibit 7).

Exhibit 7 Example of desire for career advancement as a potential source of COI

A widely held belief is that saturated fat is bad for cardiovascular health. Dr. Smith has been asked to conduct a CER comparing Drug X with Drug Y to prevent primary myocardial infarctions in U.S. populations. The participants’ dietary intake of saturated fat in the various studies was also analyzed. The findings showed that Drug X is more effective than Drug Y in preventing myocardial infarctions. The CER also found that high dietary intake of saturated fat is associated with a decreased risk of myocardial infarctions independent of Drug X or Drug Y. Dr. Smith, an assistant professor, is being considered for promotion to associate professor. Some of his mentors and peers built their academic careers reporting the harms of saturated fat. Worried that even hinting saturated fat may not be so bad could jeopardize his career advancement (or Dr. Smith fundamentally disbelieves the conclusions because of his faith in his mentors’ prior research findings), Dr. Smith decided to take on additional analyses (that were not prespecified in the SR protocol).Based on one of the additional analyses, he concluded that the association was spurious after all. Dr. Smith further buttressed that position by explaining why this particular analysis was sound, but not others.

Table 2 suggests four questions for SR team members based on the examples above. Investigators may be asked to answer additional context-specific questions. Some questions require implicit or explicit judgment about the likely direction of the review. Questions that require judgment about institutional or organizational conflict rather than individual conflict specify that respondents answer to the best of their knowledge. These questions will not identify all risks of NFCOI, given the limits of self-disclosure. In addition, PIs and funders should be prepared to review curriculum vitae of investigators on the team and consider whether to conduct searches of publication records.

Table 2 Questions to disclose nonfinancial conflicts of interest for systematic reviews

## Assessing the Risk of Bias From NFCOI

Arriving at a judgment of risk of bias from NFCOI requires caution, particularly when evaluating proxy indicators of NFCOI.7 Reviewers run the risk of biased judgment when new data conflict with viewpoints expressed in prior publications. Previously expressed viewpoints, particularly those reiterated multiple times in the literature, could represent an individual’s strongly held view on a particular issue. Factors to consider in judging the risk of bias from NFCOI include the value of the secondary interest, the scope of the relationship, and the extent to which secondary interests might exert undue influence on the primary interest, the SRs.7

## Managing the Risk of Bias From NFCOI

One helpful approach, developed by Public Responsibility in Medicine and Research, classified COI into three categories according to how they would be managed: (1) routinely allowable activities or relationships; (2) permissible activities or relationships following disclosure and review; (3) impermissible activities or relationships.21 Although this action-focused grouping is not intended to help individuals critically consider and identify their own possible conflicts, the categorization is helpful for considering possible management options. We suggest expanding the list for permissible activities to explicitly include: permissible activities after public disclosure of NFCOI, permissible activities upon expansion of the team to ensure that it includes diverse perspectives. We note that impermissible activities or relationships do not always require excluding the individual from the project: they may, in some cases, be managed by excluding the individual from certain SR activities.

We note that these actions can help mitigate risks of NFCOI at the start of the project when the team is being constituted or, if a new conflict emerges during the course of the project, as soon as the risk of conflict becomes apparent. Ad hoc actions taken during the project may not be able to mitigate the risk of bias from NFCOI.

The IOM notes that management of COI requires proportionality; that is, is the policy should be effective, efficient, and directed at the most important and most common conflicts. After evaluating the likelihood of undue influence and seriousness of possible harm, and the benefits of having the conflict outweigh the harms, the conflict may be allowed to stand.7 This reasoned approach to NFCOI management means that each type of NFCOI cannot always be managed the same way. If NFCOI had been disclosed, one or more management strategies could have been used to mitigate the risk of bias in the case examples described above. The option requiring the least change to the proposed team relies on disclosure alone. However, the discretion that conflicted team members have in important decisions in the SR process and publication may be so large that transparency alone may not sufficiently mitigate the risk of bias. Thus, we suggest using this strategy only when the level of discretion exercised by conflicted team members is unlikely to result in bias or when the input from the conflicted team member is irreplaceable.

On the opposite end of the spectrum, one management approach is to routinely exclude content area experts from review teams based on the assumption of a high level of inherent conflict. As noted earlier, we believe that such an approach risks invaliding the review because of inadequate interpretation of the findings. Nonetheless, exclusion from the review team is the appropriate management approach when conflicts of interest are likely to raise the risk of bias of the review and investigators with similar clinical or content expertise but without conflicts of interest can substitute for the conflicted team member. The greatest challenge to this approach occurs in clinical topics with a limited pool of clinical or content experts. One potential solution is to find individuals whose work is tangential or partially overlapping with the clinical area, but whose careers are unlikely to be affected by the outcome of the review.

Two other options require less drastic changes in the team but rely on more active management of conflicts during the review process. One option is to balance the conflicted team member’s perspective with an opposing view. This approach runs the risk of deadlock: opposing perspectives may fail to find common ground in the evidence. If teams elect to balance conflicted perspectives, they can avoid stalemates in decisionmaking by including methodologists with disinterested perspectives as tiebreakers, or requiring the PI or the primary author(s) to be completely free of conflict. In the example of interspecialty variations, the team could be balanced by including a spine surgeon, a general internist, and a methodologist who serves as the principal investigator.

Another option is to circumscribe the activities of conflicted team members. Conflicted investigators should never review their own research nor should they be singly responsible for analysis. In the examples of strong advocacy or active policy debate, conflicted team members could serve as technical experts rather than authors of the review. Alternatively, their input in search strategies, protocol development, analysis, and interpretation should be limited to components of the review for which they have no conflict.

## Monitoring and Reporting NFCOI: Accountability and Timing

In internally funded or self-funded projects, the PI is responsible for making team-specific decisions, and is held accountable during the peer-review process. For externally funded projects, although funders typically have the authority for final decisions, funders and lead investigators should work together to ensure that the review includes appropriate topic-related expertise and that the management of NFCOI addresses concerns of proportionality and fairness while also addressing the risk of bias. Funders may want to consider an unbiased outsider to serve as ombudsman for disputes about the management of NFCOI.As noted earlier, funders have the additional responsibility to provide guidance for NFCOI team members.

Team members should disclose NFCOI before the start of the review. Once the SR team is assembled, updates of NFCOI should be ongoing, that is, as events warrant, but no less frequently than once a year.