# Peer Reviewers

- Naomi Aaronson, Ph.D.
  Blue Cross Blue Shield Association
  Chicago, IL
- Lisa A. Bero, Ph.D.
  University of California, San Francisco
  San Francisco, CA
- Timothy S. Jost, J.D.
  Washington and Lee University
  Lexington, VA
- Robert L. Kane, M.D.
  University of Minnesota
  Minneapolis, M
- Joseph Lau, M.D.
  Tufts University
  Boston MA
- Bernard Lo, M.D.
  University of California, San Francisco
  San Francisco, CA
- George D. Lundberg, M.D.
  The Lundberg Institute
  Los Gatos, CA