# Investigator Affiliations

- Meera Viswanathan, Ph.D., Timothy S. Carey, M.D., M.P.H., and Priyanka Sista, B.A.
  RTI International–University of North Carolina at Chapel Hill Evidence-based Practice Center
  Research Triangle Park, NC
- Suzanne E. Belinson, Ph.D., M.P.H.
  Blue Cross Blue Shield Association Evidence-based Practice Center
  Chicago, IL
- Elise Berliner, Ph.D., and Stephanie Chang, M.D., M.P.H.
  Agency for Healthcare Research and Quality
  Rockville, MD
- Elaine Graham, M.L.S. and Jeanne-Marie Guise, M.D., M.P.H.
  Oregon Health Sciences University Evidence-based Practice Center
  Portland, OR
- Stanley S. Ip, M.D.
  Tufts Evidence-based Practice Center
  Boston, MA
- Margaret A. Maglione, M.P.P., and Sydne J. Newberry, Ph.D.
  RAND Evidence-based Practice Center
  Santa Monica, CA
- Douglas McCrory
  Duke University Evidence-based Practice Center
  Durham, NC
- Melissa McPheeters, M.P.H., Ph.D.
  Vanderbilt University Evidence-based Practice Center
  Nashville, TN
- C. Michael White, Pharm.D.
  University of Connecticut Evidence-based Practice Center
  Storrs, CT