# Acknowledgments

We acknowledge the contributions of Susan Norris, M.D., M.P.H, Howard Balshem, M.S., and Mark Helfand, M.D., M.S., M.P.H, who served as reviewers and Associate Editors.

We express our gratitude to the EPC editor, Laura Small, B.A., and the EPC publications specialist, Loraine Monroe.