# Conclusions

NFCOI, when ignored, can call into question the impartiality of a review. Equally, the results of a review can be invalid when management of NFCOI results in the exclusion of necessary topical expertise. This document is a consensus effort attempting to achieve the appropriate balance between supplying needed expertise and minimizing NFCOI by proposing approaches to identify and evaluate NFCOI. However, the utility of these approaches and barriers to implementation must be investigated.