# References

1 Kuntz K, Sainfort F, Butler M, et al. (2013). Decision and Simulation Modeling in Systematic Reviews. Methods Research Report.
2 Ades AE, Claxton K, Sculpher M. (2006). Evidence synthesis, parameter correlation and probabilistic sensitivity analysis. Health Econ.
3 Claxton K. (1999). The irrelevance of inference: a decision-making approach to the stochastic evaluation of health care technologies. J Health Econ.
4 Claxton K, Ginnelly L, Sculpher M, et al. (2004). A pilot study on the use of decision theory and value of information analysis as part of the NHS Health Technology Assessment programme. Health Technol Assess.
5 Philips Z, Ginnelly L, Sculpher M, et al. (2004). Review of guidelines for good practice in decision-analytic modelling in health technology assessment. Health Technol Assess.
6 Wallace BC, Trikalinos TA, Lau J, et al. (2010). Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics.
7 Russell LB, Gold MR, Siegel JE, et al. (1996). The role of cost-effectiveness analysis in health and medicine. Panel on Cost-Effectiveness in Health and Medicine. JAMA.
8 Sculpher M, Fenwick E, Claxton K. (2000). Assessing quality in decision analytic cost-effectiveness models. A suggested framework and example of application. Pharmacoeconomics.
9 Siegel JE, Weinstein MC, Russell LB, et al. (1996). Recommendations for reporting cost-effectiveness analyses. Panel on Cost-Effectiveness in Health and Medicine. JAMA.
10 Weinstein MC, Siegel JE, Gold MR, et al. (1996). Recommendations of the Panel on Cost-effectiveness in Health and Medicine. JAMA.
11 Eddy DM, Hollingworth W, Caro JJ, et al. (2012). Model transparency and validation: a report of the ISPOR-SMDM Modeling Good Research Practices Task Force-7. Med Decis Making.
12 Concannon TW, Meissner P, Grunbaum JA, et al. (2012). A new taxonomy for stakeholder engagement in patient-centered outcomes research. J Gen Intern Med.
13 (1995). Economic analysis of health care technology. A report on principles. Task Force on Principles for Economic Analysis of Health Care Technology. Ann Intern Med.
14 (2000). Decision analytic modelling in the economic evaluation of health technologies. A consensus statement. Consensus Conference on Guidelines on Economic Modelling in Health Technology Assessment. Pharmacoeconomics.
15 Andronis L, Barton P, Bryan S. (2009). Sensitivity analysis in economic evaluation: an audit of NICE current practice and a review of its use and value in decision-making. Health Technol Assess.
16 Bae EY, Lee EK. (2009). Pharmacoeconomic guidelines and their implementation in the positive list system in South Korea. Value Health.
17 Boulenger S, Nixon J, Drummond M, et al. (2005). Can economic evaluations be made more transferable?. Eur J Health Econ.
18 Brennan A, Chick SE, Davies R. (2006). A taxonomy of model structures for economic evaluation of health technologies. Health Econ.
19 Caro JJ, Briggs AH, Siebert U, et al. (2012). Modeling good research practices--overview: a report of the ISPOR-SMDM Modeling Good Research Practices Task Force--1. Value Health.
20 Chilcott J, Tappenden P, Rawdin A, et al. (2010). Avoiding and identifying errors in health technology assessment models: qualitative study and methodological review. Health Technol Assess.
21 Chiou CF, Hay JW, Wallace JF, et al. (2003). Development and validation of a grading system for the quality of cost-effectiveness studies. Med Care.
22 Cleemput I, van WP, Huybrechts M, et al. (2009). Belgian methodological guidelines for pharmacoeconomic evaluations: toward standardization of drug reimbursement requests. Value Health.
23 Clemens K, Townsend R, Luscombe F, et al. (1995). Methodological and conduct principles for pharmacoeconomic research. Pharmaceutical Research and Manufacturers of America. Pharmacoeconomics.
24 Colmenero F, Sullivan SD, Palmer JA, et al. (2007). Quality of clinical and economic evidence in dossier formulary submissions. Am J Manag Care.
25 Davalos ME, French MT, Burdick AE, et al. (2009). Economic evaluation of telemedicine: review of the literature and research guidelines for benefit-cost analysis. Telemed J E Health.
26 Detsky AS. (1993). Guidelines for economic analysis of pharmaceutical products: a draft document for Ontario and Canada. Pharmacoeconomics.
27 Drummond M, Brandt A, Luce B, et al. (1993). Standardizing methodologies for economic evaluation in health care. Practice, problems, and potential. Int J Technol Assess Health Care.
28 Drummond M, Sculpher M. (2005). Common methodological flaws in economic evaluations. Med Care.
29 Drummond M, Manca A, Sculpher M. (2005). Increasing the generalizability of economic evaluations: recommendations for the design, analysis, and reporting of studies. Int J Technol Assess Health Care.
30 Drummond M, Barbieri M, Cook J, et al. (2009). Transferability of economic evaluations across jurisdictions: ISPOR Good Research Practices Task Force report. Value Health.
31 Drummond MF, Jefferson TO. (1996). Guidelines for authors and peer reviewers of economic submissions to the BMJ. The BMJ Economic Evaluation Working Party. BMJ.
32 Evers S, Goossens M, de VH, et al. (2005). Criteria list for assessment of methodological quality of economic evaluations: Consensus on Health Economic Criteria. Int J Technol Assess Health Care.
33 Fry RN, Avey SG, Sullivan SD. (2003). The Academy of Managed Care Pharmacy Format for Formulary Submissions: an evolving standard--a Foundation for Managed Care Pharmacy Task Force report. Value Health.
34 Garattini L, Grilli R, Scopelliti D, et al. (1995). A proposal for Italian guidelines in pharmacoeconomics The Mario Negri Institute Centre for Health Economics. Pharmacoeconomics.
35 Gartlehner G, West SL, Mansfield AJ, et al. (2012). Clinical heterogeneity in systematic reviews and health technology assessments: synthesis of guidance documents and the literature. Int J Technol Assess Health Care.
36 Glennie JL, Torrance GW, Baladi JF, et al. (1999). The revised Canadian Guidelines for the Economic Evaluation of Pharmaceuticals. Pharmacoeconomics.
37 Goldhaber-Fiebert JD, Stout NK, Goldie SJ. (2010). Empirically evaluating decision-analytic models. Value Health.
38 Graf von der Schulenburg JM, Greiner W, Jost F, et al. (2008). German recommendations on health economic evaluation: third and updated version of the Hanover Consensus. Value Health.
39 Grutters JP, Seferina SC, Tjan-Heijnen VC, et al. (2011). Bridging trial and decision: a checklist to frame health technology assessments for resource allocation decisions. Value Health.
40 Hay J, Jackson J. (1999). Panel 2: methodological issues in conducting pharmacoeconomic evaluations--modeling studies. Value Health.
41 Hoomans T, Severens JL, van der RN, et al. (2012). Methodological quality of economic evaluations of new pharmaceuticals in The Netherlands. Pharmacoeconomics.
42 Karnon J, Brennan A, Akehurst R. (2007). A critique and impact analysis of decision modeling assumptions. Med Decis Making.
43 Karnon J, Goyder E, Tappenden P, et al. (2007). A review and critique of modelling in prioritising and designing screening programmes. Health Technol Assess.
44 Kolasa K, Dziomdziora M, Fajutrao L. (2011). What aspects of the health technology assessment process recommended by international health technology assessment agencies received the most attention in Poland in 2008?. Int J Technol Assess Health Care.
45 Liberati A, Sheldon TA, Banta HD. (1997). EUR-ASSESS Project Subgroup report on Methodology. Methodological guidance for the conduct of health technology assessment. Int J Technol Assess Health Care.
46 Lopez-Bastida J, Oliva J, Antonanzas F, et al. (2010). Spanish recommendations on economic evaluation of health technologies. Eur J Health Econ.
47 Lovatt B. (1996). The United Kingdom guidelines for the economic evaluation of medicines. Med Care.
48 Luce BR, Simpson K. (1995). Methods of cost-effectiveness analysis: areas of consensus and debate. Clin Ther.
49 Mason J. (1997). The generalisability of pharmacoeconomic studies. Pharmacoeconomics.
50 McCabe C, Dixon S. (2000). Testing the validity of cost-effectiveness models. Pharmacoeconomics.
51 McGhan WF, Al M, Doshi JA, et al. (2009). The ISPOR Good Practices for Quality Improvement of Cost-Effectiveness Research Task Force Report. Value Health.
52 Briggs A, Weinstein MC, Fenwick E, et al. (2012). Model Parameter Estimation and Uncertainty: A Report of the ISPOR-SMDM Modeling Good Research Practices Task Force-6. Value Health.
53 Menon D, Schubert F, Torrance GW. (1996). Canada's new guidelines for the economic evaluation of pharmaceuticals. Med Care.
54 Mullahy J. (1996). What you don't know can't hurt you? Statistical issues and standards for medical technology evaluation. Med Care.
55 Mullins CD, Ogilvie S. (1998). Emerging standardization in pharmacoeconomics. Clin Ther.
56 Mullins CD, Wang J. (2002). Pharmacy benefit management: enhancing the applicability of pharmacoeconomics for optimal decision making. Pharmacoeconomics.
57 Murray CJ, Evans DB, Acharya A, et al. (2000). Development of WHO guidelines on generalized cost-effectiveness analysis. Health Econ.
58 Blackmore CC, Magid DJ. (1997). Methodologic evaluation of the radiology cost-effectiveness literature. Radiology.
59 Canadian Coordinating Office for Health Technology Assessment. (2013). Guidelines for economic evaluation of pharmaceuticals (Brief record).
60 Neumann PJ, Stone PW, Chapman RH, et al. (2000). The quality of reporting in published cost-utility analyses, 1976-1997. Ann Intern Med.
61 Nuijten MJ, Pronk MH, Brorens MJ, et al. (1998). Reporting format for economic evaluation. Part II: Focus on modelling studies. Pharmacoeconomics.
62 Olson BM, Armstrong EP, Grizzle AJ, et al. (2003). Industry's perception of presenting pharmacoeconomic models to managed care organizations. J Manag Care Pharm.
63 Paisley S. (2010). Classification of evidence in decision-analytic models of cost-effectiveness: a content analysis of published reports. Int J Technol Assess Health Care.
64 Ramsey S, Willke R, Briggs A, et al. (2005). Good research practices for cost-effectiveness analysis alongside clinical trials: the ISPOR RCT-CEA Task Force report. Value Health.
65 Roberts M, Russell LB, Paltiel AD, et al. (2012). Conceptualizing a model: a report of the ISPOR-SMDM Modeling Good Research Practices Task Force--2. Value Health.
66 Sassi F, McKee M, Roberts JA. (1997). Economic evaluation of diagnostic technology. Methodological challenges and viable solutions. Int J Technol Assess Health Care.
67 Sculpher MJ, Pang FS, Manca A, et al. (2004). Generalisability in economic evaluation studies in healthcare: a review and case studies. Health Technol Assess.
68 Severens JL, van der Wilt GJ. (1999). Economic evaluation of diagnostic tests. A review of published studies. Int J Technol Assess Health Care.
69 Siegel JE, Torrance GW, Russell LB, et al. (1997). Guidelines for pharmacoeconomic studies. Recommendations from the panel on cost effectiveness in health and medicine. Panel on cost Effectiveness in Health and Medicine. Pharmacoeconomics.
70 Sonnenberg FA, Roberts MS, Tsevat J, et al. (1994). Toward a peer review process for medical decision analysis models. Med Care.
71 Soto J. (2002). Health economic evaluations using decision analytic modeling. Principles and practices--utilization of a checklist to their development and appraisal. Int J Technol Assess Health Care.
72 Taylor RS, Elston J. (2009). The use of surrogate outcomes in model-based cost-effectiveness analyses: a survey of UK Health Technology Assessment reports. Health Technol Assess.
73 Trikalinos TA, Siebert U, Lau J. (2009). Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Med Decis Making.
74 Udvarhelyi IS, Colditz GA, Rai A, et al. (1992). Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly?. Ann Intern Med.
75 Ungar WJ, Santos MT. (2003). The Pediatric Quality Appraisal Questionnaire: an instrument for evaluation of the pediatric health economics literature. Value Health.
76 Vegter S, Boersma C, Rozenbaum M, et al. (2008). Pharmacoeconomic evaluations of pharmacogenetic and genomic screening programmes: a systematic review on content and adherence to guidelines. Pharmacoeconomics.
77 von der SJ, Vauth C, Mittendorf T, et al. (2007). Methods for determining cost-benefit ratios for pharmaceuticals in Germany. Eur J Health Econ.
78 Weinstein MC, O'Brien B, Hornberger J, et al. (2003). Principles of good practice for decision analytic modeling in health-care evaluation: report of the ISPOR Task Force on Good Research Practices--Modeling Studies. Value Health.
79 Husereau D, Drummond M, Petrou S, et al. (2013). Consolidated Health Economic Evaluation Reporting Standards (CHEERS) statement. BMJ.
80 Bennett C, Manuel DG. (2012). Reporting guidelines for modelling studies. BMC Medical Research Methodology.
81 Husereau D, Drummond M, Petrou S, et al. (2013). Consolidated Health Economic Evaluation Reporting Standards (CHEERS) statement. BMJ.
82 Gold M. (1996). Panel on cost-effectiveness in health and medicine. Medical Care.
83 International Network of Agencies for Health Technology Assessment. (2014). Health Technology Assessment Resources.
84 Luce BR, Drummond M, Jonsson B, et al. (2010). EBM, HTA, and CER: clearing the confusion. Milbank Q.
85 Ades AE, Cliffe S. (2002). Markov chain Monte Carlo estimation of a multiparameter decision model: consistency of evidence and the accurate assessment of uncertainty. Med Decis Making.
86 Mathes T, Jacobs E, Morfeld JC, et al. (2013). Methods of international health technology assessment agencies for economic evaluations--a comparative analysis. BMC Health Serv Res.
87 Agency for Health Technology Assessment in Poland (AHTApol/Poland). (2014).
88 Canadian Agency for Drugs and Technologies in Health (CADTH/Canada). (2014).
89 Danish Centre for Health Technology Assessment (DACEHTA/Denmark). (2014).
90 Health Information and Quality Authority (HIQA/Ireland). (2014).
91 National Authority of Medicines and Health Products (INFARMED/Portugal). (2014).
92 Institute for Quality and Efficiency in Health Care (IQWIG/Germany). (2014).
93 Belgian Federal Health Care Knowledge Centre (KCE/Belgium). (2014).
94 MAS (Medical Advisory Secretariat, within the Ontario Ministry of Health and Long-Term Care Health Strategies Division). (2014).
95 Medical Services Advisory Committee (MASC/Australia). (2014).
96 National Institute for Clinical Excellence (NICE/UK). (2014).
97 Pharmaceutical Benefits Advisor Committee (PBAC, Australia). (2014).
98 Pharmaceutical Management Agency of New Zealand (PHARMAC/New Zealand). (2014).
99 AAZ (Agency for Quality and Accreditation in Health Care, Croatia). (2014).
100 National Institute for Clinical Excellence (NICE/UK). (2014).
101 ICER (Institute for Clinical and Economic Review). (2014).
102 LBI (Ludwig Boltzmann Institute for Health Technology Assessment). (2014).
103 MHRA (Medicines and Healthcare Products Regulatory Agency). (2014).
104 NLM (National Library of Medicine). (2014).
105 AHRQ (US Agency for Healthcare Research and Quality). (2014).
106 CAST (Centre for Applied Health Services Research and Technology Assessment, University of Southern Denmark). (2014).
107 CDE (Center for Drug Evaluation). (2014).
108 Agency for Healthcare Research and Quality. (2012). Guidelines and Recommendations.
109 Kuntz KM, Lansdorp-Vogelaar I, Rutter CM, et al. (2011). A systematic comparison of microsimulation models of colorectal cancer: the role of assumptions about adenoma progression. Med Decis Making.
110 Agency for Healthcare Research and Quality. (2011). The Effective Health Care Program Stakeholder Guide, Appendix C.
111 Cooper BS. (2007). Confronting models with data. J Hosp Infect.
112 Groves P, Kayyali B, Knott D, et al. (2013). The ‘big data’ revolution in healthcare. Center for US Health System Reform Business Techology Office. McKinsey & Company.
113 Behrman RE, Benner JS, Brown JS, et al. (2011). Developing the Sentinel System--a national resource for evidence development. N Engl J Med.
114 Zechmeister-Koss I, Schnell-Inderst P, Zauner G. (2013). Appropriate Evidence Sources for Populating Decision Analytic Models within Health Technology Assessment (HTA): A Systematic Review of HTA Manuals and Health Economic Guidelines. Med Decis Making.
115 Ades AE, Welton NJ, Caldwell D, et al. (2008). Multiparameter evidence synthesis in epidemiology and medical decision-making. J Health Serv Res Policy.
116 Ades AE, Caldwell DM, Reken S, et al. (2013). Evidence synthesis for decision making 7: a reviewer's checklist. Med Decis Making.
117 Dias S, Welton NJ, Sutton AJ, et al. (2013). Evidence synthesis for decision making 1: introduction. Med Decis Making.
118 Dias S, Sutton AJ, Welton NJ, et al. (2013). Evidence synthesis for decision making 6: embedding evidence synthesis in probabilistic cost-effectiveness analysis. Med Decis Making.
119 Dias S, Welton NJ, Sutton AJ, et al. (2013). Evidence synthesis for decision making 5: the baseline natural history model. Med Decis Making.
120 Dias S, Welton NJ, Sutton AJ, et al. (2013). Evidence synthesis for decision making 4: inconsistency in networks of evidence based on randomized controlled trials. Med Decis Making.
121 Dias S, Sutton AJ, Welton NJ, et al. (2013). Evidence synthesis for decision making 3: heterogeneity--subgroups, meta-regression, bias, and bias-adjustment. Med Decis Making.
122 Dias S, Sutton AJ, Ades AE, et al. (2013). Evidence synthesis for decision making 2: a generalized linear modeling framework for pairwise and network meta-analysis of randomized controlled trials. Med Decis Making.
123 ISPOR. (2012). Value in Health Guide for Authors.
124 Laine C, Goodman SN, Griswold ME, et al. (2007). Reproducible research: moving toward research the public can really trust. Ann Intern Med.
125 Peng RD. (2011). Reproducible research in computational science. Science.
126 Weinstein MC. (2006). Recent developments in decision-analytic modelling for economic evaluation. Pharmacoeconomics.
127 Morin A, Urban J, Adams PD, et al. (2012). Research priorities. Shining light into black boxes. Science.
128 Weinstein MC, Toy EL, Sandberg EA, et al. (2001). Modeling for health care and other policy decisions: uses, roles, and validity. Value Health.
129 Committee on Mathematical and Statistical Foundations of Verification VaUQ. (2012). Assessing the Realiability of Complex Models: Mathematical and Statistical Foundations of Verification,Validation,and Uncertainty Qualification.
130 Kim LG, Thompson SG. (2010). Uncertainty and validation of health economic decision models. Health Econ.
131 Berry DA, Cronin KA, Plevritis SK, et al. (2005). Effect of screening and adjuvant therapy on mortality from breast cancer. N Engl J Med.
132 Moriasi D, Wilson B, Douglas-Mankin K, et al. (2012). Hydrologic and water quality models: use, calibration, and validation. Transactions of the ASABE.
133 Legates DR, McCabe GJ. (1999). Evaluating the use of “goodness of fit measures in hydrologic and hydroclimatic model validation”. Water resources research.
134 Moriasi DN, Arnold JG, Van Liew MW, et al. (2007). Model evaluation guidelines for systematic quantification of accuracy in watershed simulations. Trans ASABE.
135 Rao C, Wu Y. (2001). On model selection.
136 Gelman A, Meng X-L, Stern H. (1996). Posterior predictive assessment of model fitness via realized discrepancies. Statistica Sinica.
137 Gelman A. (2003). A Bayesian Formulation of Exploratory Data Analysis and Goodness-of-fit Testing. International Statistical Review.
138 Gardner A, Deardon R, Darlington G. (2011). Goodness-of-fit measures for individual-level models of infectious disease in a Bayesian framework. Spat Spatiotemporal Epidemiol.
139 Deuchert E, Brody S. (2007). Plausible and implausible parameters for mathematical modeling of nominal heterosexual HIV transmission. Ann Epidemiol.
140 Hur C, Hayeck TJ, Yeh JM, et al. (2010). Development, calibration, and validation of a U.S. white male population-based simulation model of esophageal adenocarcinoma. PLoS One.
141 Ishida H, Wong JB, Hino K, et al. (2008). Validating a Markov model of treatment for hepatitis C virus-related hepatocellular carcinoma. Methods Inf Med.
142 Nijhuis RL, Stijnen T, Peeters A, et al. (2006). Apparent and internal validity of a Monte Carlo-Markov model for cardiovascular disease in a cohort follow-up study. Med Decis Making.
143 Perreault S, Levinton C, Laurier C, et al. (2005). Validation of a decision model for preventive pharmacological strategies in postmenopausal women. Eur J Epidemiol.
144 Sendi PP, Craig BA, Pfluger D, et al. (1999). Systematic validation of disease models for pharmacoeconomic evaluations. Swiss HIV Cohort Study. J Eval Clin Pract.
145 Willis M, Asseburg C, He J. (2013). Validation of economic and health outcomes simulation model of type 2 diabetes mellitus (ECHO-T2DM). J Med Econ.
146 Vanni T, Karnon J, Madan J, et al. (2011). Calibrating models in economic evaluation: a seven-step approach. Pharmacoeconomics.
147 Gourieroux C, Monfort A, Trognon A. (1984). Pseudo maximum likelihood methods: Theory. Econometrica.
148 Gong G, Samaniego FJ. (1981). Pseudo maximum likelihood estimation: theory and applications. Ann Statist.
149 Boyd SP, Vandenberghe L. (2004). Convex optimization.
150 Bertsimas D, Farias VF, Trichakis N. (2012). On the efficiency-fairness trade-off. Management Science.
151 Kuhn H, Tucker A. (2008). Nonlinear Programming Proceedings of the Second Berkeley Symposium on Mathematical Statistics and Probability.
152 Vapnik V. (1998). Statistical learning theory.
153 Stout NK, Knudsen AB, Kong CY, et al. (2009). Calibration methods used in cancer simulation models and suggested reporting guidelines. Pharmacoeconomics.
154 Earnshaw SR, Wilson M, Mauskopf J, et al. (2009). Model-based cost-effectiveness analyses for the treatment of acute stroke events: a review and summary of challenges. Value Health.
155 Rochau U, Schwarzer R, Jahn B, et al. (2014). Systematic assessment of decision-analytic models for chronic myeloid leukemia. Appl Health Econ Health Policy.
156 Abuelezam NN, Rough K, Seage GR. (2013). Individual-based simulation models of HIV transmission: reporting quality and recommendations. PLoS One.
157 Bolin K. (2012). Economic evaluation of smoking-cessation therapies: a critical and systematic review of simulation models. PharmacoEconomics.
158 Punyacharoensin N, Edmunds WJ, De AD, et al. (2011). Mathematical models for the study of HIV spread and control amongst men who have sex with men. Eur J Epidemiol.
159 Goehler A, Geisler BP, Manne JM, et al. (2011). Decision-analytic models to simulate health outcomes and costs in heart failure: a systematic review. PharmacoEconomics.
160 Haji Ali AH, Gray J, Karnon J. (2013). Model performance evaluation (validation and calibration) in model-based studies of therapeutic interventions for cardiovascular diseases : a review and suggested reporting framework.
161 Dams J, Bornschein B, Reese JP, et al. (2011). Modelling the cost effectiveness of treatments for Parkinson's disease: a methodological review. Pharmaeconomics.
162 Ferdinands JM, Mannino DM. (2008). Obstructive lung disease models: what is valid?. COPD.
163 Unal B, Capewell S, Critchley JA. (2006). Coronary heart disease policy models: a systematic review. BMC Public Health.
164 Siebert U, Bornschein B, Walbert T, et al. (2004). Systematic assessment of decision models in Parkinson's disease. Value Health.
165 McMahon PM, Kong CY, Johnson BE, et al. (2012). Chapter 9: The MGH-HMS lung cancer policy model: tobacco control versus screening. Risk Anal.
166 Kong CY, McMahon PM, Gazelle GS. (2009). Calibration of disease simulation model using an engineering approach. Value Health.
167 Kohli M, Ferko N, Martin A, et al. (2007). Estimating the long-term impact of a prophylactic human papillomavirus 16/18 vaccine on the burden of cervical cancer in the UK. Br J Cancer.
168 Taylor DC, Pawar V, Kruzikas D, Gilmore KE, Pandya A, Iskandar R, Weinstein MC. (2010). Methods of model calibration: observations from a mathematical model of cervical cancer. Pharmacoeconomics.
169 Karnon J, Vanni T. (2011). Calibrating models in economic evaluation: a comparison of alternative measures of goodness of fit, parameter search strategies and convergence criteria. Pharmacoeconomics.
170 Karnon J, Delea T, Barghout V. (2008). Cost utility analysis of early adjuvant letrozole or anastrozole versus tamoxifen in postmenopausal women with early invasive breast cancer: the UK perspective. Eur J Health Econ.
171 Taylor DC, Pawar V, Kruzikas DT, et al. (2012). Incorporating calibrated model parameters into sensitivity analyses: deterministic and probabilistic approaches. PharmacoEconomics.
172 Hansen LP, Heckman JJ. (1996). The empirical foundations of calibration. J Econ Perspect.
173 Dawkins C, Srinivasan TN, Whalley J. (2001). Calibration. Handbook of econometrics.
174 Spiegelhalter DJ, Best NG. (2003). Bayesian approaches to multiple sources of evidence and uncertainty in complex cost-effectiveness modelling. Stat Med.
175 Eddy DM. (1989). The confidence profile method: a Bayesian method for assessing health technologies. Oper Res.
176 Eddy DM, Hasselblad V, Shachter R. (1990). A Bayesian method for synthesizing evidence. The Confidence Profile Method. International Journal of Technology Assessment in Health Care.
177 Eddy DM, Hasselblad V, Shachter R. (1990). An introduction to a Bayesian method for meta-analysis: The confidence profile method. Med Decis Making.
178 Eddy D, Shachter R. (1992). Meta-Analysis by the Confidence Profile Method.
179 Droitcour J, Silberman G, Chelimsky E. (1993). A new form of meta-analysis for combining results from randomized clinical trials and medical-practice databases. Int J Technol Assess Health Care.
180 Kaizar EE. (2011). Estimating treatment effect via simple cross design synthesis. Stat Med.
181 Nixon RM, Duffy SW. (2002). Cross-issue synthesis: potential application to breast cancer, tamoxifen and genetic susceptibility. J Cancer Epidemiol Prev.
182 Wald NJ, Morris JK. (2003). Teleoanalysis: combining data from different types of study. BMJ.
183 Welton NJ, Ades AE. (2005). Estimation of markov chain transition probabilities and rates from fully and partially observed data: uncertainty propagation, evidence synthesis, and model calibration. Med Decis Making.
184 Marshall EC, Spiegelhalter DJ. (2003). Approximate cross-validatory predictive checks in disease mapping models. Statistics in Medicine.
185 Rutter CM, Miglioretti DL, Savarino JE. (2009). Bayesian Calibration of Microsimulation Models. J Am Stat Assoc.
186 Basu A. (2006). Identifiability. Kotz S, Johnson N, editors. Encyclopedia of Statistical Sciences.
187 Garrett ES, Zeger SL. (2000). Latent class model diagnosis. Biometrics.
188 Jackson CH, Jit M, Sharples LD, et al. (2013). Calibration of Complex Models through Bayesian Evidence Synthesis: A Demonstration and Tutorial.
189 Whyte S, Walsh C, Chilcott J. (2011). Bayesian calibration of a natural history model with application to a population model for colorectal cancer. Med Decis Making.
190 Afzali HH, Karnon J, Merlin T. (2013). Improving the accuracy and comparability of model-based economic evaluations of health technologies for reimbursement decisions: a methodological framework for the development of reference models. Med Decis Making.
191 Haji Ali AH, Karnon J. (2011). Addressing the challenge for well informed and consistent reimbursement decisions: the case for reference models. PharmacoEconomics.
192 Cancer Intervention and Surveillance Modeling Network. (2014).
193 Mason JM, Mason AR. (2006). The generalisability of pharmacoeconomic studies: issues and challenges ahead. PharmacoEconomics.