# Preamble

Despite rigorous systematic reviews of health care interventions, patients, providers and policymakers may remain in doubt about which interventions to use because of uncertainty, tradeoffs between benefits and harms, and differences in preferences. First, even after a synthesis of best-available evidence, uncertainty may remain when evidence is available only for surrogate outcomes, or when clinical studies have small sample sizes, limited followup durations, deficiencies in their design and conduct, or do not provide sufficient information on relevant patient subgroups. Second, tradeoffs between benefits and harms occur and optimal decisionmaking for individuals and populations may depend on their values (preferences) for the different potential outcomes. Lastly, models allow consideration of the preferences of decisionmakers for different outcomes when choosing among health care interventions.

This project was designed to advance the credibility, transparency, and methodological rigor of modeling by 1) assembling a multidisciplinary modeling core methods group; 2) reviewing and evaluating current literature on best practices in prioritization, conduct, and dissemination of health care models; 3) identifying priority topics in methods research for modeling and simulation; and 4) reviewing evidence on comparisons of validation and calibration methods.

The report is written as a series of four stand-alone chapters, each in a manuscript format. Chapter 1 is a systematic review of recommendations for the conduct and reporting of health care modeling and simulation studies. Chapter 2 is a review of guidance provided by international Health Technology Assessment (HTA) web sites. Chapter 3 prioritizes future research needs to improve the conduct and reporting of modeling and simulation studies. Addressing one of the prioritized future research needs, in Chapter 4 we review reports of health care models that used multiple methods to either validate or calibrate their models.