# Peer Reviewers

Prior to publication of the final report, the EPC Program sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows.

- Eric B. Bass, M.D., M.P.H.
  Director
  Evidence-based Practice Center (EPC)
  Johns Hopkins University
  Baltimore, MD
- Andrew Briggs, D.Phil.
  William R Lindsay Chair in Health Economics,
  University of Glasgow
  Glasgow, Scotland, UK
- David B. Matchar, M.D.
  Professor and Director
  Program in Health Services and Systems Research,
  Duke-NUS Medical School
  Singapore
  Professor (Internal Medicine and Pathology),
  Duke University Medical Center
  Durham, NC
- Michael Pignone, M.D., M.P.H., F.A.C.P.
  Division of General Internal Medicine
  University of North Carolina- Chapel Hill
  Chapel Hill, NC
- Steven Teutsch, M.D., M.P.H.
  Senior Fellow
  Leonard D. Schaeffer Center for Health Policy and Economics
  University of Southern California
  Senior Fellow
  Public Health Institute
  Adjunct Professor
  UCLA Fielding School of Public Health
  Los Angeles, CA
- Evelyn Whitlock, M.D., M.P.H.
  Center for Health Research,
  Kaiser Permanente Northwest,
  Portland, OR
- Timothy J. Wilt, M.D., M.P.H.
  Minneapolis VA Health Care System
  Minneapolis, MN