# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts follows.

- Eric B. Bass, M.D., M.P.H.
  Director
  Evidence-based Practice Center (EPC)
  Johns Hopkins University
  Baltimore, MD
- Andrew Briggs, D.Phil.
  William R Lindsay Chair in Health Economics,
  University of Glasgow
  Glasgow, Scotland, UK
- Robert M. Golub, M.D.
  Deputy Editor
  JAMA
  Professor of Medicine
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Douglas Owens, M.D., M.S.
  Henry J. Kaiser, Jr. Professor,
  Director,
  VA Postdoctoral Medical Informatics Fellowship
  VA Palo Alto Health Care System
  Director
  Program on Clinical Decision Making and Guideline Development
  Center for Primary Care and Outcomes Research,
  Stanford University
  Palo Alto, CA
- J. Sanford Schwartz, M.D.
  Leon Hess Professor in Internal Medicine,
  University of Pennsylvania
  Philadelphia, PA
- Milton C. Weinstein, Ph.D.
  Henry J. Kaiser Professor of Health Policy and Management,
  Harvard Medical School
  Director
  Program on the Economic Evaluation of Medical Technology,
  Harvard T.H. Chan School of Public Health
  Boston, MA