# Acknowledgments

The authors would also like to acknowledge the contributions of Drs. William Lawrence, M.D., M.S. and Joanna Siegel, Ph.D. who served as task order officers for some of the duration of this project.