# Chapter 4 A Review of Validation and Calibration Methods for Health Care Modeling and Simulation

## Introduction

In practice, models of at least moderate complexity will be ‘solved’ with computer-based numerical analysis and simulation. Because these computer models are used to inform predictions or decisions in the real world, assessing their credibility (trustworthiness) is paramount. A recent ISPOR-SMDM Good Research Practices Task Force identified model validation as one of the two determinants of confidence in models (the other being transparency).^11^ Further, because some aspects of reality are unmeasured or unknowable, models will often require inputs for which no or only indirect data exist. In such cases, model calibration can be used to select input values that lead to model outputs “as close as possible” to available empirical data. Because model validation and calibration entail a “confrontation of models with data” they can inform judgments about the credibility of models, and can guide the use of modeling results in practical settings.

Our systematic review of evidence- and consensus-based guidance on the conduct and reporting of modeling and simulation studies (Chapter 1) identified model calibration and validation as a major methodological research area. This was triangulated by a panel of multiple stakeholders, including developers and users of health care models, who also identified aspects of model evaluation, and model validation and calibration in particular, as important targets for future methodological research. There is limited previous work surveying calibration and validation methods used for health care models and most existing reviews have either focused on a limited topic area (e.g., treatment of cardiovascular disease, cancer natural history) or modeling methodology (e.g., micro-simulation models).

Based on the above, we conducted a project aiming to provide a unifying overview of validation and calibration methods, and a survey of studies comparing validation and calibration methods used in health care modeling and simulation studies.

## Methods

### Sources of Information and Review Methods

Issues pertaining to model evaluation and assessment arise in many methodological disciplines (e.g., mathematics and statistics, economics, theory of simulation, operations research), as well as many topic areas (e.g., health care, disease modeling, biology, environmental science, mechanical engineering, material science). The relevant literature is vast, poorly categorized in standard literature databases (i.e., specific search terms are lacking), and published as journal papers, conference proceedings, books, and technical reports that are not always easy to identify, obtain, and comprehend. Thus, a comprehensive systematic review of all relevant methodological papers was deemed infeasible. Instead, we relied on a mixed approach that combined consultation with expert methodologists; hand-searching the reference lists of related papers, technical reports, and books; review of our personal reference collections; and a systematic review of studies comparing validation and calibration methods for disease modeling-related or health care-related models.

The systematic component of our literature review covered four electronic databases (MEDLINE, Cochrane Methodology Register, Health Technology Assessment Database, NHS Economic Evaluation Database), through June 3, 2013, for articles presenting validation and calibration methods in reports of modeling and simulation studies. We also rescreened the citations retrieved by the search strategy of our recently completed systematic review of recommendations for the conduct and reporting of modeling and simulation studies. The final search strategy, with the list of 37 included journals, is presented in Appendix B.

Six reviewers independently screened 6825 abstracts in duplicate and resolved disagreements by group consensus. Eligible studies had to compare or apply at least two methods related to model validation, model calibration, or goodness of fit, in the context of modeling or simulation. We excluded studies that applied only a single method of validation or calibration. Three reviewers extracted descriptive information from included articles. Completed data extraction forms were verified by a second reviewer and were discussed during group meetings. Extracted data included population characteristics, outcomes, basic model description, and methods and results related to model validation and calibration.

### Definitions and Preliminaries

By ‘modeling’ we mean a multistep iterative process to conceptualize, by abstraction and idealization, a representation of salient aspects of reality (conceptual model), specify it mathematically (mathematical model) and implement it in computer code (computational model) so that it can be ‘solved’. Figure 3 outlines the modeling process. Because the modeled natural phenomena can be complex and the model implementation process is often intricate, it is important to perform checks throughout. Terminology about these checks varies across fields and topic areas, but the underlying concepts are similar.

Figure 3 Diagram of the modeling process

A flow diagram of the modeling process.Model output is impacted by nature, conceptual model, mathematical model and computational model, all under expert opinion. Flowing into and out of model output are data and other models.

In this work we use the terms ‘verification,’ ‘assessment of face-validity,’ ‘validation,’ and ‘calibration’ to describe various checks. Verification refers to assessing the correctness of the mathematical structure (e.g., absence of mistakes in the logic), and of the implementation of the computational model (e.g., absence of software ‘bugs’, suitability of numerical algorithms). Face-validity refers to whether the model is deemed a satisfactory representation of the salient aspects of reality and whether the model results appear to be plausible. We use the term calibration to describe the process of determining the values of parameters so that model outputs match (i.e., “fit”) observed empirical data. We define validation to be the comparison of model outputs with expert judgment, observed data, or other models, without any attempt to modify model parameters to improve fit. A more detailed description of types of model validation is provided in the next section.

## Overview of Validation and Calibration Methods

### Overview of Model Validation

Validation is the assessment of the “congruence” between model predictions and actual observed data, or the results of other models addressing the same (or similar) research question, or expert predictions of what the results should be. The literature identifies several aspects of model validation, including face validity, verification and internal validation, cross-model comparisons, external validation, and prospective and predictive validation.^11,50,129,130^ To a large extent, the descriptions provided below follow those adopted by the recent ISPOR-SMDM Modeling Good Research Practices Task Force.^11^

- Face validity (“first order” validation) refers to the determination, by a suitable group of experts, that the model reflects the current understanding of the science and available evidence. Expert review should cover all aspects of the modeling process, including the question formulation, model structure, model data, and the model output. Evaluation of aspects of modeling other than the model output, are best performed “blinded” to the model results to reduce the possibility of biased assessment.
- Verification and internal validation (“second order” validation) refers to an assessment of whether the model has been implemented correctly and behaves as expected. Verification can pertain to the computer code (“code verification”) and the solutions that it produces in well-understood problems with known solutions (“solution verification”).^129^ Some consider the comparison of model outputs with the data used to populate the model to be a component of internal validity. However, when using a study to estimate model parameters only a small part of the study results are used; in which case other data can be used for validation. For example, if a randomized trial is used to inform a model regarding the relationship between treatment (e.g., statin vs. no statin) and a surrogate outcome (e.g., LDL cholesterol at 6 months), the trial data on other outcomes (e.g., mortality, morbidity) can be used for model validation.^11^
- External validation (“third order” validation): In external validation, the model outputs are compared with empirical observations that were not used in model development. As noted above, external validation is sometimes taken to mean the comparison of model outputs against observations in datasets that are disjoint from those used in model development. In general, external validation using disjoint data provides a more stringent assessment of model performance.
- Prospective and predictive validation (“fourth order” validation) assess the model's ability to reproduce (“predict”) empirical results that were not available and were not used during its development.^130^ Prospective validation refers to the use of data that accrues over additional followup in studies that were used for model development. Predictive validation refers to the use of data from independent studies that were unavailable at the time of model development.
- Cross-model validation involves a comparison of results among different models for the same (or sufficiently similar) analyses.^11^ Such comparisons can increase the credibility of the models and provide methodological insights. Cross-model comparisons have been used extensively in cancer simulation models supported by the Cancer Intervention and Surveillance Modeling Network (CISNET).^131^

Two general types of methods are in common use for internal, external, and prospective or predictive validation: ‘informal’ methods using graphical and tabular presentations of model results (e.g., time series and scatter plots, cumulative frequency distributions) and ‘formal’ (statistical) using a distance function or goodness-of fit metric.^132^ The value of graphical and tabular data displays cannot be overemphasized. However, these methods may not always have adequate sensitivity for detecting poor fit to the data and are operator dependent. For this reason, graphical methods are usually combined with statistical methods. The latter rely on assessments of goodness-of-fit that quantify the discrepancy between observed data and model outputs;^133,134^ in many ways these quantitative assessments are similar to standard model fit criteria used in statistics.^135^ When a Bayesian approach is adopted, posterior predictive checks (i.e., comparisons between the observed data and the model's posterior predictive distribution) can be used to assess model fit.^136,137^ For example, Gardner (2011) proposed and studied alternative model fit statistics for individual-level infectious disease models, based on posterior predictive checks.^138^

It is not possible to identify a universally preferred method for statistical model validation.^129^ However, some general principles to guide the choice are identified in the literature: first, statistical validation should be applied to quantities of interest that are relevant to the model scope and the perspective of the analysis. Second, statistical criteria for model fit need to be appropriate for the mathematical structure of the model.^129^ For example, if there is dependence (clustering) in the statistical model (e.g., repeat measurements within individuals or groups) the statistical criteria should account for that dependence. Third, because model fit is generally improved by increasing the number of model parameters (which may lead to over-fitting the data used for model development and limit generalizability), criteria that “account for” the number of model parameters may be preferable. Fourth, any statistical method for model validation should take into account uncertainty in both the empirical data and the model outputs.

More generally, it is not possible to establish model validity in the affirmative; i.e., there is no criterion that, if met, establishes a model as generally valid. In fact, some experts suggest that it is only possible to demonstrate model invalidity in a specific setting and for a specific purpose (e.g., by showing that model predictions do not fit a set of observations that is relevant to the anticipated model use).^11^

### Empirical Studies of Model Validation

Our searches for studies using alternative model assessment methods identified several studies that applied various approaches to assess model fit.^130,138-145^ This list is obviously not exhaustive, in that it is limited to health care applications and is based on a systematic, but non-comprehensive process for identifying relevant studies. We found that validation methods were specific to the research question that was addressed by each study and the investigators' choice of methods for model implementation. For these reasons, we did not use them to draw general conclusions.

### Overview of Model Calibration

Calibration involves the optimization of a subset of model parameters to improve the fit of model predictions to empirical data. Traditionally, calibration is distinguished from other estimation tasks by its use to obtain estimates for parameters for which only indirect data is available. For example, in microsimulation models of cancer in humans, parameters for which direct empirical data are unavailable (e.g., growth rates of preclinical cancers) are determined by selecting input rate values to produce model outputs (e.g., cancer incidence rates, which are functionally dependent on the parameters for which direct data are unavailable) that “are as close as possible” to empirical data.

Calibration efforts are tailored to the specific needs of a particular model. Calibration is fundamentally an optimization (estimation) problem. To specify a calibration problem, one has to define the following components:

- Calibration parameters are the typically weakly identifiable (e.g., supported by indirect evidence) model parameters that are subjected to calibration.^43^ A most important issue is whether the feasible domain of the calibration parameters is convex or not. This is because convex calibration problems (problems where the parameter domain and the objective functions are convex) can be solved easier than non-convex ones.
- Calibration targets are the data against which the model output is compared; calibration aims to select parameter values that produce model outputs that are “close” to the calibration targets (while “close” may be assessed graphically or visually, it is preferably encoded quantitatively by an objective function). The choice of calibration targets depends on the model quantities of interest, the availability of “high quality” data, and the goals of modeling. For example, when calibrating a model, the calibration targets should be derived from data relevant to the decisional context, and obtained from well-designed and conducted studies of populations “similar” to those who will be affected by the decision.
- Objective functions are typically scalar functions of the calibration parameters used to assess “closeness” quantitatively. Common choices include a distance of the calibration target data from model outputs, a convexity-preserving transformation of a distance, or a likelihood or pseudo-likelihood.^133,134,146-148^ Example distances are the sum of absolute or squared differences between model outputs and calibration targets (L1- and L2-norms, respectively). Examples of convexity-preserving transformations of distances are various chi-squared statistics. Distances are convex objective functions, and for many problems the likelihood and pseudo-likelihood is convex as well. As mentioned above, convexity of the objective function is an important property, because convex problems are much easier to solve than non-convex ones.

The goal is to solve (optimize) the calibration problem, that is, identify the feasible values of the calibration parameters that optimize the objective function. Solving the calibration problem entails defining the following:

- Algorithm for optimizing the objective function. These algorithms search for values of calibration parameters in the feasible domain that optimize the objective function. Principled searching uses mathematical programming to obtain values. Descriptions of ad hoc approaches, such as ‘manual’-tuning, however, also occur in the health care literature.
- Acceptance criteria are used to determine whether an algorithm has converged to a solution. Typically, this means that further iterations do not change the value of the objective function and the estimated values of the calibration parameters beyond prespecified tolerances (strict tolerances can be of the order of machine precision).
- The stopping rule is the criterion for terminating the calibration process. Usually, calibration is stopped when the acceptance criteria are satisfied, the search space is exhausted (e.g., all points in a grid search have been evaluated), or a predetermined maximum number of iterations has been reached.

As mentioned already, the solution of the calibration problem (identifying the global optimum of the objective function within the feasible domain of the calibration parameters) depends greatly on the objective function and the shape of the feasible domain of the calibration targets. When the problem is convex (both the objective function and the feasible domain are convex) or can be restated to be convex, a single optimum exists and the mathematical programming methods to find it are very robust, representing a readily-usable technology.^149^ Problems that are not convex—or cannot be recast as convex—have local optima, and demand global optimization approaches. For such problems, exact solutions often become computationally expensive, and only approximate solutions may be practical.

Based on the above, we make the following general observations, which are important for interpreting the empirical research found in the health care literature:

- Judging which specification of the calibration problem (in particular, which objective function) is most appropriate is not answerable from data alone. This is a general statement for optimization problems. The choice of the objective function should reflect the decisionmakers' perspective, and the nature of the problem.^150^ Thus comparisons of solutions to alternative objective functions are difficult to interpret.
- From a theoretical basis, solutions to different specifications of the calibration problem clearly need not be identical. We interpret empirical demonstrations of this phenomenon in specific applications as stability analyses.
- Once a calibration problem has been specified, it is straightforward to rank the different optimization algorithms according to their performance, by ordering (within machine precision) the value that the (scalar) objective function has with each algorithm's solution. To learn from such comparisons one must (a) be confident that the algorithms were implemented correctly and efficiently; and (b) be able to characterize salient mathematical attributes of the calibration problem, e.g., whether common regularity conditions were met.^149,151,152^ Because this requires a very deep understanding of the problem at hand and of the mechanics of the various algorithms, it is generally not possible to draw generalizable conclusions.

### Empirical Studies of Model Calibration

Our search for studies comparing alternative calibration methods for health care models identified four relevant studies (Table 7). They include comparisons between different specifications of the calibration problem solved with the same algorithm, or with different algorithms; and comparisons between alternative algorithms for the same calibration problem, that highlighted various mathematical aspects. Further, each empirical study was limited to a single modeled process (and the same model was examined in 2 of the 4 studies). Many reported results (e.g., running time, performance, etc.) are expected to be dependent on the specific computer implementation. Thus, we deem that it is not possible to draw general conclusions from these studies.

Table 7 Studies comparing alternative calibration methods applied to the same problem

Author, year | Area of application | Model structure | Methods compared | Study findings
Kong, 2009^165,166^ | Lung cancer development, progression, detection, treatment, and survival (Lung Cancer Policy Model) | Agent-based; state transition model; 1 month cycle length | - Search algorithms (simulated annealing vs. genetic algorithm) | - Both search algorithms attained study-determined threshold GOF scores within 1000 search iterations; - Simulated annealing outperformed the genetic algorithm; - The model predictions after calibrations matched other mathematical models of cancer development
Taylor, 2010^167,168^ | Cervical cancer epidemiology, natural history, and effectiveness of vaccination | Cohort-based; 6-state Markov model; 6-month cycle length; lifetime horizon; implemented in Excel with Visual Basic for Applications. | - Search algorithms (‘manual’ calibration vs. random search of parameter domain vs. Nelder-Mead) | - The Nelder-Mead algorithm and manual calibration achieved the best fit (weighted mean percent deviations of 7% and 10%, respectively); random search performed poorly (weighted mean percent deviation of 39%); - Use of the Nelder-Mead algorithm required less analyst time but was more computationally demanding, compared with manual calibration.
Karnon, 2011^169,170^ | Choice of adjuvant chemotherapy for early breast cancer | Cohort-based; Markov model; 1 year cycle length; 50-year time horizon; implemented in Excel with an add-on component (Microsoft Excel Solver; Frontline Systems). | - GOF metrics (chi-square vs. likelihood); - Search algorithms (random vs. gradient-based guided search); - Alternative convergence criteria (narrow vs. broad) | - The chi-square GOF metric “differentiated between the accuracy of different parameter sets” to a greater than the log-likelihood statistics; - The guided search strategy produced results of higher accuracy and greater precision than random search; - Broader convergence criteria produced less accurate results that were closer to the non-calibrated results
Taylor, 2012^167,171^ | Cervical cancer epidemiology, natural history, and effectiveness of vaccination | Cohort-based; 6-state Markov model; 6-month cycle length; lifetime horizon | - Alternative starting values for the Nelder-Mead search algorithm (5, randomly chosen); - GOF metrics [weighted MPD with weights for the cancer incidence and mortality parameters that were 6- and 3-fold larger that those of corresponding carcinoma in situ endpoints (1-6-3 weights) vs. MPD with 1-3-3 weights vs. MSPD with 1-3-3 weights vs. MSPD with 1-3-6 weights vs. ML] | - The sensitivity/stability analyses to the choice of initial values and alternative weighting schemes revealed a substantial amount of uncertainty in the model output – far greater than that revealed by forward propagation of uncertainty

GOF = goodness-of-fit; ML = maximum likelihood; MPD = mean percentage deviation; MSPD = mean squared percentage deviation.

### Methodological Appraisals of Validation and Calibration Methods

Several systematic methodological appraisals of health care models and simulations provide information on the validation and calibration methods used in practice. These studies have found that more than half of all modeling studies do not report any use of calibration or validation methods.^43,153-164^ When some aspect of model validation or calibration is mentioned, reporting is often incomplete. Below, we review the results of methodological appraisals that provided a more in depth assessment of validation and calibration methods.

#### Cancer

Stout (2009) reviewed 131 studies of cancer microsimulation models that could have used calibration methods to determine input values for unobservable parameters.^153^ Approximately 50 percent of the studies (n=66) referred to “calibration” or “model fitting” and an additional 16 percent (n=21) provided references to methodological publications on model calibration. Nearly all studies (95%, n=83 of 87) identified the calibration targets they used, 54 percent (n=47) reported information on the goodness-of-fit metric used. Information on the search algorithms used was not well described. The authors used the results of this investigation to derive a 7-item “Calibration Reporting Checklist,” which may be useful as a reminder of issues to consider when evaluating calibration methods in modeling studies.

#### Cardiovascular Disease

Haji Ali Afzali (2013) reviewed 81 model-based studies (including cohort and agent-based models) for cardiovascular disease.^160^ They found that 73 percent (59 studies) reported some element of model evaluation, but only 6 percent (5 studies) reported a calibration process. Usually multiple calibration targets were employed in each study but only a single study provided information on the goodness-of-fit metric and no studies reported information on the acceptance criteria. Search algorithms were generally not well documented.

Unal (2006) reviewed the methodology of 42 coronary heart disease models (reported in 75 publications).^163^ In general validation and calibration methods were not used systematically and were not reported in detail. Six of the 42 models were considered “principal coronary heart disease models” – of these, two reported some calibration procedure and only one reported the performance of model validation.

#### Neurological Disease

Siebert (2004) reviewed 8 studies using mathematical models to evaluate treatments for Parkinson's disease.^164^ None of the eight studies reported any internal or external validation of their models. Dams (2011) surveyed 11 cost-effectiveness studies for Parkinson's disease including therapeutic and diagnostic evaluations.^161^ They found that only four models reported performing some form of model validation and none provided adequate details of their validation methods and results.

#### Respiratory Disease & Smoking Cessation

Ferdinands (2008) reviewed 13 disease simulation models of asthma or chronic obstructive pulmonary disease (11 state-transition models and 2 dynamic population models).^162^ Only two studies provided information on code and solution verification; seven studies reported comparisons of model outputs with data used to develop the model; seven studies reported results of external validation; and no studies reported performing predictive validation or plans to undertake such efforts.

Bolin (2012) assessed 78 economic evaluations of smoking cessation therapies,^157^ 30 of which were considered “highly relevant” (defined as studies applying “intertemporal modeling with a time horizon” of at least 20 years). They found that “several studies”^b^ used simulation models – that were not described as previously validated – without performing any model validation.

### Calibration as Estimation

As outlined above, calibration is very similar to statistical estimation.^172,173^ Both processes have the same goal, namely to find input values that lead to the best possible model fit. For example, if the objective function of the calibration is a likelihood function, calibration is—by most any definition—equivalent to maximum likelihood estimation. The conceptualization of calibration as estimation is helpful when assessing the identifiability of the parameters of the mathematical model and examining the consistency between data inputs.

As an example, we consider simulation models that use meta-analysis to inform some of their inputs. First, note that the empirical data inputs for the model comprise two potential approaches and two types of data (1) meta-analysis-estimation of input data to estimate some model parameters, and (2) calibration-estimation in which calibration targets are used to estimate the remaining model parameters. Modelers have two options: do the meta-analysis-estimation and the calibration-estimation separately (as two steps; most common practice) or jointly (in one step; least common). We make the following observations about one-step versus two-step procedures:

- Compared with one-step estimation, two-step estimation is generally less efficient (in the statistical sense) and does not guarantee that the best-fitting values for parameters will be identified. It can also hinder the complete characterization of parameter uncertainty and the representation of correlations between data sources or dependencies among model parameters. The one-step method is consistent with the scientific maxim of using all available evidence when making decisions. Further, it may help avoid under-assessments of uncertainty. The one-step approach is closely related to methods for synthesizing evidence from diverse sources, including multi-parameter and generalized evidence synthesis,^115,174^ the confidence profile method,^175-178^ cross-design synthesis,^179-181^ and teleo-analysis.^182^
- One-step estimation allows for formal tests of consistency of parameter estimates obtained by different sources of evidence. One-step approaches enable an assessment of whether the various data sources ‘square up’. If the data are inconsistent (do not ‘square up’), a serious problem exists that requires resolution (discussion of possible methods for resolving inconsistencies is beyond the scope of the current work).^85,183^ If the data are consistent, the one-step approach maximizes use of all of the available information.
- One-step estimation allows one to use well-established quantitative methods for comparing differences between model outputs and empirical data while using all available data.^184^ Examples of such methods include posterior predictive checks, posterior mean deviance statistics, and various model cross-validation approaches.
- Under some circumstances, which can be formalized, the one-step approach and the two-step approach (as described above) are mathematically equivalent.^c^

#### Parameter Identifiability

The ability of Bayesian methods to incorporate external information or subjective beliefs, in the form of informative prior distributions, is particularly appealing when some model parameters are unidentifiable. For example, Rutter (2009) used a Bayesian approach to calibrate a microsimulation model of colorectal cancer natural history.^185^ Briefly, a model of colorectal cancer natural history was programmed and prior distributions were specified for all model parameters. Markov Chain Monte Carlo (MCMC) methods were used to estimate model parameters using data from multiple sources. For parameters that were unidentifiable using available data, informative prior distributions were specified; these distributions appropriately accounted for parameter uncertainty (as opposed to fixing the parameters to arbitrary values). The finite sample size performance of the proposed methodology was assessed in a simulation study, which demonstrated that the proposed method was an unbiased estimator for parameters for which data were available.

Nonetheless, jointly performing calibration and estimation of model parameters does not eliminate problems of identifiability: model parameters for which there is only limited (e.g., indirect) or no information are effectively unidentifiable.^186^ Their posterior distribution is determined by the prior distribution chosen for them. In addition, in complex models, identifiability is hard to assess by just examining the model equations or inspecting the posterior distributions it produces. Instead, quantitative assessment is necessary. In the above-mentioned colorectal cancer microsimulation study,^185^ informative prior distributions were specified for unidentifiable model parameters and the model diagnostics proposed by Garrett & Zeger (2000) were used to assess identifiability via overlap statistics.^187^ The utility of this approach was also demonstrated in the aforementioned simulation study.^185^

#### Examples of Calibration as Estimation

In addition to Rutter (2009),^185^ other examples of using Bayesian methods for model calibration, validation, and parameter estimation exist, both for health care and non-health care models and simulations. These studies vary in their complexity, the number of data sources and the amount of information available for model development and evaluation.^188,189^ Jackson (2013) and Whyte (2011) provide tutorials on using Bayesian evidence synthesis methods and provide code and data to reproduce the analyses.^188,189^

## Conclusions

This chapter provides an overview of the state-of-the science on model validation and calibration for health care models. It appears that in health care, methodological research on the calibration and validation of models has been limited to case-studies applying a small number of alternative approaches to a small number of models. Because such case studies produce results that are applicable to these particular models, and address only a small part of the complex and multifaceted methodological decisions that modelers make, we believe that there is need for further research on validation and verification methods.

Based on our review of the literature and discussions with the stakeholders (described in Chapter 1), we have identified the following broad areas for future research, with a focus on areas that may be of interest to the Effective Health Care Program:

- Consideration should be given to the development of default (“reference”) models to facilitate the use of validated models as adjuncts to systematic reviews.^190,191^ Because model validation and calibration are time consuming activities and because systematic reviews need to be prepared in a timely fashion, the use of modeling in systematic reviews could be facilitated by developing and validating reference models for high-impact conditions (e.g., as has been done in CISNET).^192^ Such conditions could be selected among AHRQ's priority areas, by taking into consideration the potential value of using models to supplement reviews of published evidence in each area.
- Further research is needed for the development, validation, and calibration of complex models that incorporate evidence from multiple sources. Systematic reviews (e.g., comparative effectiveness reviews prepared by Evidence-based Practice Centers) often retrieve evidence that is flawed (as indicated by risk of bias assessments), indirect (e.g., addressing laboratory surrogates instead of clinical outcomes), incomplete (e.g., with missing data), and conflicting (clinically and methodologically heterogeneous). Under these conditions “global subjective assessments” of the evidence are prone to error (and bias).^178^ Modeling can address these problems by synthesizing evidence in a statistically valid way and allowing a formal assessment of consistency, while making all assumptions explicit.
- Research is needed to determine “best practices” for validating and calibrating models that are intended for use across different settings and patient populations.^67,193^ Such methods would rely on developing criteria for formalizing judgments on the adequacy of the validation process (especially external, prospective, and predictive validation).
- Given the importance of cross-model validation (especially in the absence of relevant empirical data) and the increasing availability of models addressing the similar research questions further research in needed to explore how discrepancies among models relate to the models' potential for being prospectively and externally validated (against data).
- Methodological work is also needed to identify optimal methods for communicating (e.g., visualizing) the validation and calibration methods used in complex models. Such research is necessary for presenting complex models to applied modelers and – more importantly – lay “consumers” of modeling and simulation results.

In summary, model validation and calibration are fundamental processes for establishing the credibility of models and simulations. “Confronting models with data” is an important component of establishing their validity and correct parameterization.^111^ Ongoing progress in statistical, operational, and computational methods can provide modelers with an expanding toolkit for validating and calibrating models. However, current empirical research is limited to methodological appraisals or case-studies of alternative methods. Future research should advance our understanding of the theoretical basis of model evaluation and use comprehensive simulation methods to compare alternative approaches.

b An exact count was not provided in the main text of the paper and the supplementary appendix was not downloadable from the journal Web site.

c For example, this is true when the objective function is differentiable and the gradient of the objective function with respect to the calibration parameters is not a function of the remaining (other) parameters in the mathematical model, and the gradient of the objective function with respect to the other parameters is not a function of the calibration parameters.